# List of Abbreviations

AAFP: American Academy of Family Physicians
Add Health: National Longitudinal Study of Adolescent Health
ADHD: attention deficit hyperactivity disorder
AFRO: WHO Africa
AHA: American Heart Association
ALA: American Lung Association
AMA: American Medical Association
ASSIST: American Stop Smoking Intervention Study
B&W: Brown & Williamson Tobacco Corporation
BAT: British American Tobacco
BHR: bronchial hyperresponsiveness
BMI: body mass index
BRFSS: Behavioral Risk Factor Surveillance System
CAI: computer-assisted interviewing
CARDIA: Coronary Artery Risk Development in Young Adults
CDC: Centers for Disease Control and Prevention
CEO: chief executive officer
CHIPS: Choosing Healthy Influences for a Positive Self
CI: confidence interval
COMMIT: Community Intervention Trial for Smoking Cessation
COPD: chronic obstructive pulmonary disease
CSAP: Center for Substance Abuse Prevention
CT: computed tomography
D.A.R.E.: Drug Abuse Resistance Education
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders- 4th edition
DVD: digital video disc
DZ: dizygotic
EDI: Eating Disorders Inventory
ED-NOS: eating disorders-not otherwise specified
EMRO: WHO Eastern Mediterranean
ES: effect size
ESFA: European Smoking Prevention Framework Approach
ESPAD: European School Survey Project on Alcohol and Other Drugs
EURO: WHO Europe
FCC: Federal Communications Commission
FCP: Full Court Press
FCTC: Framework Convention for Tobacco Control
FDA: U.S. Food and Drug Administration
FEF: forced expiratory flow
FEF_25–75_: FEF between 25% and 75% of forced vital capacity
FEV_1_: forced expiratory volume in 1 second
FLAVOR: Fun Learning about Vitality, Origin, and Respect
FOK: Focus on Kids
FTC: Federal Trade Commission
FTND: Fagerström Test of Nicotine Dependence
FTQ: Fagerström Tolerance Questionnaire
FVC: forced vital capacity
g: gram
GABA: gamma-aminobutyric acid
GNAT: Go/No-go Association Test
GRP: gross rating point
GTSS: Global Tobacco Surveillance System
GYTS: Global Youth Tobacco Survey
HDL: high-density lipoprotein
HONC: Hooked on Nicotine Checklist
HSI: Heaviness of Smoking Index
IARC: International Agency for Research on Cancer
IAT: Implicit Association Test
ICC: intraclass correlation coefficient
ICV: Internet cigarette vendors
IMBC: Integrated Model of Behavior Change
ImPACT: Informed Parents and Kids Together
IMPACT: Initiatives to Mobilize for the Prevention and Control of Tobacco Use
IOM: Institute of Medicine
IRR: incidence rate ratio
ISAAC: International Study of Asthma and Allergies in Childhood
ISFP: Iowa Strengthening Families Program
ITT: intent to treat
kg: kilogram
L: liter
LCA: latent class analysis
LDL: low-density lipoprotein
Legacy: American Legacy Foundation
LST: LifeSkills Training
LTA: latent transition analysis
MDD: major depressive disorder
mFTQ: modified Fagerström Tolerance Questionnaire
mg: milligram
MI: myocardial infarction
mL: milliliter
mm: millimeter
MPAA: Motion Picture Association of America
MPP: Midwestern Prevention Project
MRI: magnetic resonance imaging
MSA: metropolitan statistical area
MSS: Minnesota Student Survey
MTF: Monitoring the Future
MVPA: moderate-to-vigorous intensity physical activity
MZ: monozygotic
NAAG: National Association of Attorneys General
nAChR: nicotinic acetylcholine receptor
NARE: negative affect relief expectancy
NASBE: National Association of State Boards of Education
NCI: National Cancer Institute
NDSS: Nicotine Dependence Syndrome Scale
NELS: National Education Longitudinal Study
NHANES: National Health and Nutrition Examination Survey
NHIS: National Health Interview Survey
NIH: National Institutes of Health
NLSY97: National Longitudinal Survey of Youth 1997 Cohort
NPM: nonparticipating manufacturer
NSDUH: National Survey on Drug Use and Health
NYTCP: New York Tobacco Control Program
NYTS: National Youth Tobacco Survey
OECD: Organisation for Economic Co-operation and Development
OPM: original participating manufacturer
OR: odds ratio
OSH: Office on Smoking and Health
PAHO: WHO Pan American Health Organization
PDAY: Pathobiological Determinants of Atherosclerosis in Youth
PEF: peak expiratory flow
PFDY: Preparing for the Drug Free Years
PSU: primary sampling unit
PUP: possession, use, and purchase
QALY: quality-adjusted life year
RCT: randomized controlled trial
RI: relative improvement
RICO: Racketeer Influenced and Corrupt Organizations Act
RJR: R.J. Reynolds Tobacco Company
RR: relative risk
SAMHSA: Substance Abuse and Mental Health Services Administration
SCQ: Smoking Consequences Questionnaire
SCQ-S: Smoking Consequences Questionnaire-Spanish
SD: standard deviation
SEARO: WHO South-East Asia
SES: socioeconomic status
SEU: subjective expected utility
SHOUT: Students Helping Others Understand Tobacco
SIDS: sudden infant death syndrome
SMART: Self-Management and Resistance Training
SNP: single nucleotide polymorphisms
SOS: Solutions for Smoking
SPM: subsequent participating manufacturer
SSQ: Smoking Situations Questionnaire
SYMATU: Statewide Youth Movement Against Tobacco Use
TAPP: Tobacco and Alcohol Prevention Project
TCP: tobacco prevention and control program
TNT: Project Towards No Tobacco Use
TPB: Theory of Planned Behavior
TPSAC: Tobacco Product Scientific Advisory Committee
TRA: Theory of Reasoned Action
TRP: total rating point
TTI: Theory of Triadic Influence
TUTD: Thumbs Up! Thumbs Down! Project
UCSF: University of California, San Francisco
UNC: University of North Carolina
URI-TW: upper respiratory infection-triggered wheezing
USDA: U.S. Department of Agriculture
USDHHS: U.S. Department of Health and Human Services
USDHEW: U.S. Department of Health, Education, and Welfare
USPS: United States Postal Service
USPSTF: U.S. Preventive Services Task Force
VLDL: very-low-density lipoprotein
VTA: ventral tegmental area
WCSS: Weight Control Smoking Scale
WHO: World Health Organization
WPRO: WHO Western Pacific
YRBS: Youth Risk Behavior Survey
YRBSS: Youth Risk Behavior Surveillance System