# Supplemental Evidence Tables

## Chapter 6. Cancer

Table 6.3S Case-control studies on smoking and primary liver cancer

Table 6.4S Cohort studies on smoking and primary liver cancer

Table 6.5S Prospective studies of cigarette smoking and colorectal cancer incidence, published 2002–2009

Table 6.6S Case-control studies of cigarette smoking and colorectal cancer incidence, published 2001–2008

Table 6.7S Prospective studies of cigarette smoking and colorectal cancer mortality, published 2002–2009

Table 6.8S Prospective cohort studies on the association between cigarette smoking and prostate cancer incidence and mortality

Table 6.9S Epidemiologic cross-sectional studies on the association between cigarette smoking and stage and histologic grade at diagnosis of prostate cancer

Table 6.10S Cohort studies on the association between cigarette smoking and risk of prostate cancer progression, case fatality, and all-cause mortality in men with prostate cancer

Table 6.11S Reports on levels of endogenous hormones and smoking in premenopausal women (n = 22)

Table 6.12S Reports on levels of endogenous hormones and smoking in postmenopausal women (n = 17)

Table 6.14S Cohort study reports of the association between active cigarette smoking and risk of breast cancer, based on studies published before 2012 (n = 15)

Table 6.15S Case-control study reports of the association between active cigarette smoking and risk for breast cancer, based on studies published from 2000 to 2011 (n = 34)

Table 6.16S Evaluation of reports on exposure to active cigarette smoking for meta-analyses, based on cohort studies before 2012 and case-control studies published between 2000 and 2011 for meta-analyses, by location, study design, size of analytic sample, type of referent group, meta-analysis categories, and design or analysis issues (n = 65)

Table 6.17S Summary of meta-analyses for measures of active cigarette smoking for all studies combined and stratified by study design, based on cohort studies published before 2012 and case-control studies published from 2000 to 2011

Table 6.18S Reports of premenopausal and postmenopausal relative risks (RRs) by study and meta-analysis RRs for the association of active smoking (ever, pack-years) with risk for breast cancer, based on cohort studies published before 2012 and case-control studies published from 2000 to 2011 (n = 20)

Table 6.19S Reports of estrogen receptor status relative risks (RRs) for the association of active cigarette smoking (ever, cigarettes/day) with risk for breast cancer, based on cohort studies published before 2012 and case-control studies published from 2000 to 2011 (n = 17)

Table 6.20S Reports on the association between active cigarette smoking and risk of a second primary contralateral breast cancer (n = 7)

Table 6.21S Modification of risk for breast cancer associated with smoking by NAT2 phenotype, based on two meta-analyses and one pooled analysis, stratified by menopausal status

Table 6.22S Reports on case-control studies of the association between exposure to secondhand smoke and relative risk (RR) for breast cancer incidence,based on studies published before 2012 but not included in the 2006 Surgeon General's report (n = 7)

Table 6.23S Reports on case-control studies of the association between exposure to secondhand smoke and relative risk for breast cancer incidence, based on studies published before 2012 but not included in the 2006 Surgeon General's report (n = 11)

Table 6.24S Evaluation of reports on exposure to secondhand smoke among 171 nonsmokers, based on 10 cohort and 24 case-control studies of breast cancer published before 2012 for meta-analyses, by location, study design, analytic sample size, meta-analysis categories, and design or analysis issues (n = 39)

Table 6.25S Summary of meta-analyses for the broadest categories of exposure to secondhand smoke (adult–any source, ever in lifetime, most comprehensive) for all studies of breast cancer combined and stratified by menopausal status, based on cohort and case-control studies published before 2012

Table 6.26S Summary of meta-analyses for specific categories of exposure to secondhand smoke (spouse, home, workplace, childhood, childhood and adulthood) for all studies of breast cancer combined and stratified by menopausal status, based on cohort and case-control studies published before 2012

Table 6.27S Comparison of relative risks (RRs) from selected summaries of meta-analyses for active smoking versus exposure to secondhand smoke for all studies of breast cancer combined and stratified by study design

Table 6.28S Associations between smoking and overall mortality in cancer patients

Table 6.29S Associations between smoking and overall survival in cancer patients

Table 6.30S Associations between smoking and cancer-related mortality

Table 6.31S Associations between smoking and developing a second primary cancer in cancer patients

Table 6.32S Associations between smoking and cancer recurrence

Table 6.33S Associations between smoking and cancer response

Table 6.34S Associations between smoking and treatment-related toxicity in cancer patients

## Chapter 7. Respiratory Diseases

Table 7.2S Population-based cohort studies of cigarette smoking and asthma induction in children and adolescents

Table 7.3S Studies of cigarette smoking and asthma induction in adults

Table 7.4S Studies of cigarette smoking, exacerbation of asthma, and natural history in adults

Table 7.5S Studies on tobacco use and tuberculosis (TB) infection

Table 7.6S Studies on tobacco use and tuberculosis (TB) disease

Table 7.7S Studies on tobacco use and recurrent tuberculosis (TB)

Table 7.8S Studies on tobacco use and tuberculosis (TB) mortality

Table 7.10S Studies of risk of cigarette smoking and idiopathic pulmonary fibrosis (IPF), 1990–2011

## Chapter 8. Cardiovascular Diseases

Table 8.6S Detailed description of studies on smokefree laws and coronary events

Table 8.7S Detailed description of studies on smokefree laws and cerebrovascular accidents

Table 8.8S Detailed description of studies on the relationship between smokefree laws and other heart disease

## Chapter 9. Reproductive Outcomes

Table 9.3S Summary of studies of orofacial clefts and maternal smoking, 2002–2011

Table 9.4S Summary of studies of maternal smoking and clubfoot, 1999–2011

Table 9.5S Summary of studies of maternal smoking and gastroschisis, 1999–2011

Table 9.6S Summary of studies of maternal smoking and congenital heart defects, 1999–2011

Table 9.7S Summary of studies of maternal smoking and craniosynostosis, 1999–2011

Table 9.8S Summary of studies of maternal smoking and anorectal atresia, 1999–2011

Table 9.10S Studies on associations between prenatal smoking and disruptive behavioral in children, 2000–2012

Table 9.11S Studies on associations between prenatal smoking and anxiety and depression in children, 2000–2012

Table 9.12S Studies on the associations between prenatal smoking and Tourette syndrome in children, 2000–2011

Table 9.13S Studies on associations between prenatal smoking and intellectual disability in children, 2000–2009

Table 9.14S Association between maternal smoking and ectopic pregnancy, studies included in 2001–2010 Surgeon General's reports and subsequently published through March 2013

Table 9.15S Studies on the effect of maternal active smoking on spontaneous abortion (SAB) risk

Table 9.16S Experimental studies of the association between smoking and erectile dysfunction

Table 9.17S Cross-sectional studies of the association between smoking and the risk of erectile dysfunction

## Chapter 10. Other Specific Outcomes

Table 10.1S Summary of evidence from case-control studies on the association between smoking and age-related macular degeneration (AMD)

Table 10.2S Summary of evidence from cross-sectional studies on the association between smoking and age-related macular degeneration (AMD)

Table 10.3S Summary of evidence from prospective cohort studies on the association between smoking and age-related macular degeneration (AMD)

Table 10.4S Summary of evidence from other types of studies on the association between smoking and age-related macular degeneration (AMD)

Table 10.5S Studies on the association between active smoking and dental caries

Table 10.6S Studies on exposure to tobacco smoke and dental caries

Table 10.7S Studies on smoking and failure of dental implants

Table 10.8S Characteristics of studies included in the meta-analysis on smoking and diabetes

Table 10.14S Studies on the association between smoking and rheumatoid arthritis (RA) risk

Table 10.15S Studies on the association between smoking and rheumatoid arthritis (RA) severity

Table 10.16S Studies on the association between smoking and rheumatoid arthritis (RA) treatment response

Table 10.17S Studies on the association between smoking and systemic lupus erythematosus (SLE) risk

Table 10.18S Studies on the association between smoking and systemic lupus erythematosus (SLE) severity and manifestations

Table 10.19S Studies on smoking and systemic lupus erythematosus (SLE) treatment response

Table 10.20S Characteristics of the studies on the effects of current smoking on Crohn's disease or ulcerative colitis

Table 10.21S Characteristics of the studies on the effects of former smoking on Crohn's disease or ulcerative colitis

## Chapter 11. General Morbidity and All-Cause Mortality

Table 11.1S Studies on the association between smoking and all-cause mortality

Table 11.2S Studies on the association between smoking and poor general health

Table 11.3S Studies on the association between smoking and relative risk of poor functional status

Table 11.4S Studies on the association between smoking and SF-36 or SF-12 scores

Table 11.5S Studies on the association between smoking and other measures of health and function

Table 11.6S Studies on the association between smoking and hospitalizations

Table 11.7S Studies on the association between smoking and outpatient visits

Table 11.8S Studies on the association between smoking and nursing home stays

Table 11.9S Studies on the association between smoking and costs

Table 11.10S Annual per capita spending on health care, by smoking status and age group (2008 dollars)

Table 11.11S Studies on the association between smoking and workplace absenteeism (days absent)

Table 11.12S Studies on the association between smoking and relative risk (RR) of workplace absenteeism