# Acknowledgments

This report was prepared by the U.S. Department of Health and Human Services under the general direction of the Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health.

- Rear Admiral (RADM) Boris D. Lushniak, M.D., M.P.H., Acting Surgeon General, U.S. Public Health Service, Office of the Assistant Secretary for Health, Office of the Surgeon General, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.
- Howard K. Koh, M.D., M.P.H., Assistant Secretary for Health, U.S. Department of Health and Human Services, Washington, D.C.
- Thomas R. Frieden, M.D., M.P.H., Director, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Ursula E. Bauer, Ph.D., M.P.H., Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Samuel F. Posner, Ph.D., Associate Director for Science (Acting), Editor in Chief, Preventing Chronic Disease: Public Health Research, Practice and Policy, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Tim A. McAfee, M.D., M.P.H., Director, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

## The editors of the report were

- Jonathan M. Samet, M.D., M.S., Senior Scientific Editor, Professor and Flora L. Thornton Chair, Department of Preventive Medicine, Keck School of Medicine; Director, Institute for Global Health, University of Southern California, Los Angeles, California.
- Terry F. Pechacek, Ph.D., Senior Associate Editor, Deputy Director for Research Translation, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Leslie A. Norman, M.B.A., Managing Editor, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Peter L. Taylor, M.B.A., Technical Editor, Fairfax, Virginia.

## Contributing authors were

- David B. Abrams, Ph.D., Executive Director, The Schroeder Institute for Tobacco Research and Policy Studies, Professor, Department of Health, Behavior and Society, The Johns Hopkins Bloomberg School of Public Health, Baltimore, Maryland, and Professor of Oncology (adjunct), Georgetown University Medical Center, Lombardi Comprehensive Cancer Center, Washington, D.C.
- Anthony J. Alberg, Ph.D., M.P.H., Blatt Ness Professor, Department of Public Health Sciences, Associate Director of Cancer Prevention and Control, Hollings Cancer Center, Medical University of South Carolina, Charleston, South Carolina.
- Gary P. Anderson, Ph.D., Director, Centre for Lung Health Research, Department of Pharmacology and Therapeutics and Department of Medicine, Faculty of Medicine, Dentistry and Health Sciences, The University of Melbourne, Australia.
- Brent M. Ardaugh, M.P.H., M.S., Science Writer, Framingham Heart Study, Boston University School of Medicine, Boston, Massachusetts.
- Kathy B. Baumgartner, Ph.D., Professor and Associate Dean for Faculty Affairs, Department of Epidemiology and Population Health, School of Public Health and Information Sciences, The Henry Vogt Professorship in Cancer Prevention and Control, James Graham Brown Cancer Center, University of Louisville, Louisville, Kentucky.
- Richard N. Baumgartner, Ph.D., Professor and Chair, Department of Epidemiology and Population Health, School of Public Health and Information Sciences, University of Louisville, Louisville, Kentucky.
- Neal L. Benowitz, M.D., Professor of Medicine, Bioengineering, and Therapeutic Sciences, Chief, Division of Clinical Pharmacology, University of California, San Francisco, California.
- Rebecca H. Bitsko, Ph.D., Health Scientist, Division of Human Development and Disability, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Georgiy V. Bobashev, Ph.D., Senior Research Statistician, Research Triangle Institute, Durham, North Carolina.
- Kari Bohlke, Sc.D., Consultant Epidemiologist, Alvin J. Siteman Cancer Center, Washington University School of Medicine in St. Louis, St. Louis, Missouri.
- Ross C. Brownson, Ph.D., Professor and Co-Director, Prevention Research Center in St. Louis, Brown School; Division of Public Health Sciences and Alvin J. Siteman Cancer Center, School of Medicine, Washington University in St. Louis, St. Louis, Missouri.
- Arthur L. Burnett, M.D., M.B.A., F.A.C.S., Patrick C. Walsh Distinguished Professor of Urology, Cellular and Molecular Medicine, Director, Sexual Medicine Division, Department of Urology, Johns Hopkins University, Baltimore, Maryland.
- David M. Burns M.D., Professor Emeritus, Department of Family and Preventive Medicine, University of California San Diego, School of Medicine, San Diego, California.
- Angelika H. Claussen, Ph.D., Research Psychologist, Division of Human Development and Disabilities, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Graham A. Colditz, M.D., Dr. P.H., Fellow of the Australian Faculty of Public Health Medicine, Niess-Gain Professor and Chief, Division of Public Health Sciences, Department of Surgery, Washington University School of Medicine, and Associate Director, Prevention and Control, Siteman Cancer Center, St. Louis, Missouri.
- David Coultas, M.D., Vice President for Clinical and Academic Affairs, Professor and Chair, Department of Medicine, The University of Texas Health Science Center, Tyler Texas.
- James D. Crapo M.D., Professor of Medicine, National Jewish Health and University of Colorado, Denver, Colorado.
- MeLisa R. Creamer, M.P.H., Ph.D. Candidate and Michael and Susan Dell Health Scholar, Division of Epidemiology, University of Texas School of Public Health, Austin Regional Campus, Michael and Susan Dell Center for Healthy Living, Austin, Texas.
- Mary E. Cronin, M.D., Rheumatology Fellowship Program Director, Professor of Medicine, Medical College of Wisconsin, Milwaukee, Wisconsin.
- K. Michael Cummings, Ph.D., M.P.H., Co-director, Tobacco Research Program, Hollings Cancer Center and Professor, Department of Psychiatry and Behavioral Sciences, Medical University of South Carolina, Charleston, South Carolina.
- Nancy E. Davidson, M.D., Director, University of Pittsburgh Cancer Institute and University of Pittsburgh Medical Center, Associate Vice Chancellor for Cancer Research, Hillman Professor of Oncology, Distinguished Professor of Medicine and Pharmacology and Chemical Biology, University of Pittsburgh, Pittsburgh, Pennsylvania.
- Richard A. Daynard, J.D., Ph.D., President, Public Health Advocacy Institute, University Distinguished Professor of Law, Northeastern University, Boston, Massachusetts.
- Cristine D. Delnevo, Ph.D., M.P.H., Director, Center for Tobacco Surveillance and Evaluation Research, Professor and Chair, Department of Health Education/Behavioral Science, Rutgers School of Public Health, New Brunswick, New Jersey.
- Dawn L. DeMeo, M.D., M.P.H., Channing Division of Network Medicine, Associate Professor of Medicine, Harvard Medical School, Associate Physician, Division of Pulmonary and Critical Care, Brigham and Women's Hospital, Boston, Massachusetts.
- Mark D. Eisner, M.D., M.P.H., Associate Professor of Medicine and Anesthesia, Division of Occupational and Environmental Medicine and Division of Pulmonary and Critical Care Medicine, Department of Medicine, University of California, San Francisco, California.
- Lucinda England, M.D., M.S.P.H., Medical Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Jonathan Golub, Ph.D, M.P.H., Associate Professor, Medicine, Epidemiology and International Health, Center for Tuberculosis Research, Johns Hopkins University, Baltimore, Maryland.
- Mark Gottlieb, J.D., Executive Director, Public Health Advocacy Institute, Northeastern University School of Law, Boston, Massachusetts.
- Stephen S. Hecht, Ph.D., Wallin Professor of Cancer Prevention, Masonic Cancer Center, University of Minnesota, Minneapolis, Minnesota.
- Jack E. Henningfield, Ph.D., Vice President, Research and Health Policy, Pinney Associates, Bethesda, Maryland, and Professor, Adjunct, Behavioral Biology, Department of Psychiatry and Behavioral Sciences, The Johns Hopkins University School of Medicine, Baltimore, Maryland.
- Theodore R. Holford, Ph.D., Professor, Department of Biostatistics, Yale School of Public Health, New Haven, Connecticut.
- Stephen T. Holgate M.D., Professor, Fellow of the Academy of Medical Sciences, Medical Research Council, Clinical Professor of Immunopharmacology, University of Southampton, United Kingdom.
- John W. Holloway, Ph.D., Professor of Allergy and Respiratory Genetics, Faculty of Medicine, University of Southampton, United Kingdom.
- David M. Homa, Ph.D., M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Margaret A. Honein, Ph.D., M.P.H., Chief, Birth Defects Branch, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Frank B. Hu, M.D., Ph.D., Professor of Nutrition and Epidemiology, Harvard School of Public Health; Professor of Medicine, Harvard Medical School and Department of Medicine, Brigham and Women's Hospital, Boston, Massachusetts.
- Susan Hutfless, Ph.D., Assistant Professor, Division of Gastroenterology and Hepatology, Department of Medicine, Johns Hopkins University, Baltimore, Maryland.
- Rachel Kaufmann, M.P.H., Ph.D., Associate Director for Science, Center for Surveillance, Epidemiology, and Laboratory Services, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Brian A. King, Ph.D., M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Gregory D. Kirk, M.D., M.P.H., Ph.D., Associate Professor of Epidemiology, Medicine and Oncology, Johns Hopkins University, Baltimore, Maryland.
- Kim Klausner, Manager, Industry Documents Digital Libraries, University of California San Francisco, San Francisco, California.
- Robert C. Klesges, Ph.D., Professor, Department of Preventive Medicine, The University of Tennessee Health Science Center, Memphis, Tennessee.
- Darwin R. Labarthe, M.D., M.P.H., Ph.D., F.A.H.A., Professor of Preventive Medicine, Department of Preventive Medicine, Northwestern University Feinberg School of Medicine, Chicago, Illinois.
- Anne Landman, B.A., Landman Research and Communications, Grand Junction, Colorado.
- David T. Levy, Ph.D., Professor, Cancer Control, Lombardi Comprehensive Cancer Center, Georgetown University, Washington, D.C.
- Carolyn A. Lullo, Ph.D., M.S., Public Health Analyst, Division of Human Development and Disability, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Patricia L. Mabry, Ph.D., Senior Advisor and Acting Deputy Director, Office of Behavioral and Social Sciences Research, Office of the Director, National Institutes of Health, Bethesda, Maryland.
- David M. Mannino, M.D., Professor and Chair, Department of Preventive Medicine and Environmental Health, Director, Pulmonary Epidemiology Research Laboratory, University of Kentucky College of Public Health, Lexington, Kentucky.
- Paul Melstrom, Phar.D., Ph.D., Toxicologist/Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- David Méndez, Ph.D., Associate Professor, Health Management and Policy, School of Public Health, University of Michigan, Ann Arbor, Michigan.
- Nathaniel D. Osgood, Ph.D., Director, Computational Epidemiology and Public Health Informatics Laboratory, Associate Professor, Department of Computer Science, Associate Faculty, Department of Community Health and Epidemiology, University of Saskatchewan, Saskatoon, Canada.
- Mark Parascandola, Ph.D., M.P.H., Epidemiologist, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Bethesda, Maryland.
- Terry F. Pechacek, Ph.D., Deputy Director for Research Translation, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Cheryl L. Perry, Ph.D., Professor and Regional Dean, University of Texas School of Public Health, Austin Regional Campus, Michael and Susan Dell Center for Healthy Living, Austin, Texas.
- Keydra L. Phillips, M.Sc., Health Scientist, Division of Birth Defects and Developmental Disabilities, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Elizabeth A. Platz, Sc.D., M.P.H., Professor, Department of Epidemiology, Johns Hopkins Bloomberg School of Public Health and the Sidney Kimmel Comprehensive Cancer Center at Johns Hopkins University, Baltimore, Maryland.
- Jennita Reefhuis, Ph.D., Research Health Scientist, Division of Reproductive Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Nancy A. Rigotti, M.D., Director, Tobacco Research and Treatment Center and Associate Chief, General Medicine Division, Department of Medicine, Massachusetts General Hospital; Professor of Medicine, Harvard Medical School, Boston, Massachusetts.
- Ann K. Rosenthal, M.D., Will and Cava Ross Professor of Medicine, Chief of Rheumatology and Vice Chair, Department of Medicine, Medical College of Wisconsin, Milwaukee, Wisconsin.
- Hossein Sadeghi-Nejad, M.D., F.A.C.S., Professor of Surgery, Division of Urology, Rutgers New Jersey Medical School, Chief of Urology, Virginia-New Jersey Health Care System; Director, Center for Male Reproductive Medicine, Hackensack University Medical Center, Hackensack, New Jersey.
- Jonathan M. Samet, M.D., M.S., Professor and Flora L. Thornton Chair, Department of Preventive Medicine, Keck School of Medicine; Director, Institute for Global Health, University of Southern California, Los Angeles, California.
- Elizabeth Selvin, Ph.D., M.P.H., Associate Professor of Epidemiology and Medicine, Welch Center for Prevention, Epidemiology and Clinical Research, Johns Hopkins Bloomberg School of Public Health, Baltimore, Maryland.
- Steven D. Shapiro, M.D., Executive Vice President and Chief Medical and Scientific Officer, University of Pittsburgh Medical Center; President, Physician Services Division; Professor of Medicine, University of Pittsburgh School of Medicine, Pittsburgh, Pennsylvania.
- Peter G. Shields, M.D., Deputy Director, Comprehensive Cancer Center, Professor, College of Medicine, James Cancer Hospital, The Ohio State University Wexner Medical Center, Columbus, Ohio.
- Donald R. Shopland, U.S. Public Health Service (retired), Ringgold, Georgia.
- David Sidransky, M.D., Director, Head and Neck Cancer Research Division, Professor in Otolaryngology, Cellular and Molecular Medicine, The Johns Hopkins University School of Medicine, Baltimore, Maryland.
- Edwin K. Silverman, M.D., Ph.D., Associate Professor of Medicine, Harvard Medical School, Associate Physician, Brigham and Women's Hospital, Boston, Massachusetts.
- Martin R. Stampfli, Ph.D., Professor, Department of Pathology and Molecular Medicine, McMaster Immunology Research Centre, and Department of Medicine, Firestone Institute of Respiratory Health at St. Joseph's Healthcare, McMaster University, Hamilton, Ontario, Canada.
- Melissa H. Stigler, Ph.D., M.P.H., Assistant Professor, The University of Texas Health Science Center at Houston, School of Public Health, Austin Regional Campus, Michael and Susan Dell Center for Healthy Living, Austin, Texas.
- Edward L. Sweda, Jr., J.D., Senior Attorney, Public Health Advocacy Institute, Northeastern University School of Law, Boston, Massachusetts.
- Rachel Taketa, Library Specialist, Industry Documents Digital Libraries, Library and Center for Knowledge Management, University of California, San Francisco, California.
- Gerald W. Talcott, Ph.D., ABPP, Col USAF (ret), Director of Military Research, Associate Professor, Department of Preventive Medicine, University of Tennessee Health Science Center, Memphis, Tennessee.
- Leslie A. Thompson, M.D., Division of Rheumatology, Department of Medicine, Medical College of Wisconsin, Milwaukee, Wisconsin.
- Michael J. Thun, M.D., Vice President Emeritus, Epidemiology and Surveillance Research, American Cancer Society, Atlanta, Georgia.
- Hilary A. Tindle, M.D., M.P.H, Assistant Professor of Medicine, Epidemiology, and Clinical and Translational Science, University of Pittsburgh, Pittsburgh, Pennsylvania.
- Scott L. Tomar, D.M.D., M.P.H., Dr. P.H., Professor, Department of Community Dentistry and Behavioral Science, University of Florida College of Dentistry, Gainesville, Florida.
- Van T. Tong, M.P.H., Epidemiologist, Division of Reproductive Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Andrea C. Villanti, Ph.D., M.P.H., Associate Director for Regulatory Science and Policy, The Schroeder Institute for Tobacco Research and Policy Studies, American Legacy FoundationS, Washington, D.C.
- Susanna N. Visser, M.S., Lead Epidemiologist, Division of Human Development and Disability, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Kala Visvanathan, M.B.B.S., F.R.A.C.P., M.H.S., Associate Professor, Department of Epidemiology, Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.
- Kenneth E. Warner, Ph.D., Avedis Donabedian Distinguished University Professor of Public Health, Department of Health Management and Policy, School of Public Health, University of Michigan, Ann Arbor, Michigan.
- Graham Warren M.D., Ph.D., Vice Chairman for Research in Radiation Oncology, Associate Professor, Department of Radiation Oncology, Department of Cell and Molecular Pharmacology, Hollings Cancer Center, Medical University of South Carolina, Charleston, South Carolina.
- Sheila West, Ph.D., El Maghraby Professor, Vice Chair for Research, Wilmer Eye Institute, School of Medicine, Johns Hopkins University, Baltimore, Maryland.
- Heather Wipfli, Ph.D., Associate Director, Institute for Global Health, Assistant Professor, Department of Preventive Medicine and School of International Relations, Keck School of Medicine, University of Southern California, Los Angeles, California.
- Xin Xu, Ph.D., Senior Economist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Mitchell Zeller, J.D., Senior Vice President, Pinney Associates, Bethesda, Maryland.

## Reviewers were

- David B. Abrams, Ph.D., Executive Director, The Schroeder Institute for Tobacco Research and Policy Studies, Professor, Department of Health, Behavior and Society, The Johns Hopkins Bloomberg School of Public Health, Baltimore, Maryland, and Professor of Oncology (adjunct), Georgetown University Medical Center, Lombardi Comprehensive Cancer Center, Washington, D.C.
- Anthony J. Alberg, Ph.D., M.P.H., Blatt Ness Professor, Department of Public Health Sciences, Associate Director of Cancer Prevention and Control, Hollings Cancer Center, Medical University of South Carolina, Charleston, South Carolina.
- Ashwin N. Ananthakrishnan, M.D., M.P.H, Assistant Professor of Medicine, Division of Gastroenterology, Massachusetts General Hospital and Harvard Medical School, Boston, Massachusetts.
- Benjamin Apelberg, Ph.D., M.H.S., Chief, Epidemiology Branch, Division of Population Health Sciences, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Rockville, Maryland.
- Erik M. Augustson, Ph.D., M.P.H., Behavioral Scientist, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Olalekan A. Ayo-Yusuf, D.D.S., M.P.H., Ph.D., Head of Clinical Unit and Associate Professor, Department of Community Dentistry, University of Pretoria, Pretoria, South Africa.
- Cathy L. Backinger, Ph.D., M.P.H., Deputy Director for Research, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Rockville, Maryland.
- John A. Baron, M.D., Professor of Medicine, University of North Carolina, Chapel Hill, North Carolina.
- Leslie Bernstein, Ph.D., Director and Professor, Division of Cancer Etiology, Department of Population Sciences, Beckman Research Institute, City of Hope, and Dean for Faculty Affairs, Office of Academic Affairs, City of Hope, Duarte, California.
- Douglas W. Bettcher, M.D., M.P.H., Ph.D., Director, Prevention of Noncommunicable Diseases Department, Noncommunicable Diseases and Mental Health Cluster, World Health Organization, Geneva, Switzerland.
- Mary Beth Bigley, Dr.P.H., M.S.N., A.N.P., Director, Division of Science and Communications, and Acting Editor, Public Health Reports, Office of the Surgeon General, Office of the Assistant Secretary for Health, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.
- Michele Bloch, M.D., Ph.D., Chief, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Ron Borland Ph.D., Nigel Gray Distinguished Fellow in Cancer Prevention, Research Division, Cancer Council Victoria, Australia.
- Thomas H. Brandon, Ph.D., Director, Tobacco Research and Intervention Program, and Chair, Department of Health Outcomes and Behavior, Moffitt Cancer Center; Professor of Psychology and Oncologic Sciences, University of South Florida, Tampa, Florida.
- Otis W. Brawley, M.D., Chief Medical and Scientific Officer, American Cancer Society; Professor, Departments of Hematology and Oncology, Medicine and Epidemiology, Emory University, Atlanta, Georgia.
- Peter A. Briss, M.D., M.P.H., Medical Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Gerald Brock, M.D., Professor of Surgery, Urology Program Director, The University of Western Ontario, Vice President of Education, Canadian Urological Association, London, Ontario, Canada.
- Paul A. Bunn, Jr., M.D., James Dudley Chair in Cancer Research, University of Colorado Cancer Center, Aurora, Colorado.
- Gregory L. Burke, M.D., M.Sc., Professor and Chair, Division of Public Health Sciences, Wake Forest University School of Medicine, Winston-Salem, North Carolina.
- David M. Burns M.D., Professor Emeritus, Department of Family and Preventive Medicine, University of California San Diego School of Medicine, San Diego, California.
- Tim Byers M.D., M.P.H., Associate Director for Cancer Prevention and Control, University of Colorado Cancer Center, Associate Dean for Public Health Practice at the Colorado School of Public Health, Aurora, Colorado.
- Neil E. Caporaso, M.D., Chief, Genetic Epidemiology Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Rockville, Maryland.
- Richard Casaburi, Ph.D., M.D., Medical Director, Rehabilitation Clinical Trials Center, Los Angeles Biomedical Research Institute at Harbor-University of California Los Angeles Medical Center; Professor of Medicine, University of California Los Angeles, School of Medicine, Torrance, California.
- Frank J. Chaloupka, Ph.D., Director, Health Policy Center, University of Illinois at Chicago, Distinguished Professor, Department of Economics, University of Illinois, Chicago, Illinois.
- June M. Chan, Sc.D., Professor, Epidemiology and Biostatistics, and Urology, Steven and Christine Burd-Safeway Distinguished Professor, University of California, San Francisco, California.
- Graham A. Colditz, M.D., Dr. P.H., Fellow of the Australian Faculty of Public Health Medicine, Niess-Gain Professor and Chief, Division of Public Health Sciences, Department of Surgery, Washington University School of Medicine, and Associate Director, Prevention and Control, Siteman Cancer Center, St. Louis, Missouri.
- Gregory N. Connolly, D.M.D., M.P.H., Professor of Public Health Practice, Director, Center for Global Tobacco Control, School of Public Health, Harvard University, Boston, Massachusetts.
- Karen H. Costenbader, M.D., M.P.H., Associate Professor of Medicine, Harvard Medical School; Associate Physician and Co-Director of Lupus Center, Division of Rheumatology, Immunology and Allergy, Brigham and Women's Hospital, Boston, Massachusetts.
- James D. Crapo, M.D., Professor of Medicine, National Jewish Health and University of Colorado Denver, Denver, Colorado.
- Amanda J. Cross, Ph.D., Investigator, Nutritional Epidemiology Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Rockville, Maryland.
- K. Michael Cummings, Ph.D., M.P.H., Co-director, Tobacco Research Program, Hollings Cancer Center and Professor, Department of Psychiatry and Behavioral Sciences, Medical University of South Carolina, Charleston, South Carolina.
- Thomas Dietrich, D.M.D., M.D., M.P.H., Professor and Chair, Department of Oral Surgery, School of Dentistry, University of Birmingham, Birmingham, United Kingdom.
- Carolyn Dresler, M.D., M.P.A., Associate Director of Medical and Health Sciences, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Rockville, Maryland.
- Bruce A. Dye, D.D.S., M.P.H., U.S. Public Health Service, Dental Epidemiology Officer, Centers for Disease Control and Prevention, National Center for Health Statistics, Division of Health and Nutrition Examination Statistics, Hyattsville, Maryland.
- Hashem B. El-Serag, M.D., M.P.H., Professor, Department of Medicine, Chief of Gastroenterology and Hepatology, Baylor College of Medicine, and Chief, Clinical Epidemiology and Outcomes, Michael E. DeBakey Department of Veterans Affairs Medical Center, Houston, Texas.
- Michael Eriksen, Sc.D., Dean and Professor, School of Public Health, Georgia State University, Atlanta, Georgia.
- Eric J. Feuer, Ph.D., Chief, Statistical Methodology and Applications Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Lawrence J. Fine, M.D., Dr. P.H., Chief, Clinical Applications and Prevention Branch, Division of Cardiovascular Sciences, National Heart, Lung, and Blood Institute, Bethesda, Maryland.
- David W. Fleming, M.D., Director and Health Officer for Public Health, Seattle and King County, Seattle, Washington.
- Silvia Franceschi, M.D., Special Advisor, Head, Infections and Cancer Epidemiology Group, International Agency for Research on Cancer, Lyon, France.
- Neal D. Freedman, Ph.D., M.P.H., Investigator, Nutritional Epidemiology Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Rockville, Maryland.
- Gary D. Friedman, M.D., M.S., Consulting Professor of Epidemiology, Department of Health Research and Policy, Stanford University School of Medicine; Adjunct Investigator (Former Director), Division of Research, Kaiser Permanente Medical Care Program of Northern California, Stanford, California.
- Philip S. Gardiner, Dr. P.H., Program Officer, Policy and Regulatory Sciences, Nicotine Dependence and Neurosciences, Tobacco-Related Disease Research Program, Office of the President, University of California, Oakland, California.
- Joseph Gfroerer, Chief, Population Survey Branch, Division of Surveillance and Data Collection, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Gretchen Gierach, Ph.D., M.P.H., Investigator, Hormonal and Reproductive Epidemiology Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Rockville, Maryland.
- Elizabeth Ginexi, Ph.D., Health Scientist/Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Edward L. Giovannucci, M.D., Sc.D., Professor of Nutrition and Epidemiology, Harvard School of Public Health; Associate Professor of Medicine, Brigham and Women's Hospital, Harvard Medical School, Harvard University, Boston, Massachusetts.
- Gary A. Giovino, Ph.D., M.S., Professor and Chair, Department of Community Health and Health Behavior, School of Public Health and Health Professions, The State University of New York at Buffalo, Buffalo, New York.
- Stanton A. Glantz, Ph.D., Professor of Medicine and American Legacy Foundation Distinguished Professor in Tobacco Control; Director, Center for Tobacco Control Research and Education, University of California, San Francisco, California.
- Thomas J. Glynn, Ph.D., Director, Cancer Science and Trends; Director, International Cancer Control, American Cancer Society, Washington, DC.
- David C. Goff, Jr., M.D., Ph.D., Dean and Professor, Colorado School of Public Health, Aurora, Colorado.
- Diane R. Gold, M.D., M.P.H., Professor of Medicine, Channing Laboratory, Department of Medicine, Brigham and Women's Hospital; Professor of Environmental Health, Department of Environmental Health, Harvard School of Public Health, Boston, Massachusetts.
- Richard A. Goodman, M.D., M.P.H., Senior Medical Advisor, Office of the Medical Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Rebecca F. Gottesman, M.D., Ph.D., Associate Professor of Neurology and Epidemiology, Johns Hopkins University School of Medicine, Baltimore, Maryland.
- Nigel Gray, AO, MBBS, FRACP, Honorary Senior Associate, Cancer Council Victoria, Carlton, Victoria, Australia.
- Susan Marsiglia Gray, M.P.H., Coordinator, National Synar Program, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- John D. Groopman, Ph.D., Anna M. Baetjer Professor of Environmental Health Sciences, Department of Environmental Health Sciences, Johns Hopkins Bloomberg School of Public Health, Baltimore, Maryland.
- Beth Han, M.D., Ph.D., M.P.H., Statistician, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, U.S. Department of Health and Human Services, Rockville, Maryland.
- Craig L. Hanis, Ph.D., Professor, Division of Epidemiology, Human Genetics and Environmental Sciences, University of Texas Health Science Center, Houston, Texas.
- Curtis C. Harris, M.D., Chief, Laboratory of Human Carcinogenesis, Center of Cancer Research, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Patricia Hartge, Sc.D., M.A., Deputy Director, Epidemiology and Biostatistics Program, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Bethesda, Maryland.
- Dorothy K. Hatsukami, Ph.D., Forster Family Professor in Cancer Prevention, Professor, Department of Psychiatry, University of Minnesota, Minneapolis, Minnesota.
- Stephen S. Hecht, Ph.D., Wallin Professor of Cancer Prevention, Masonic Cancer Center, University of Minnesota, Minneapolis, Minnesota.
- Jack E. Henningfield, Ph.D., Vice President, Research and Health Policy, Pinney Associates, Bethesda, Maryland, and Professor, Adjunct, Behavioral Biology, Department of Psychiatry and Behavioral Sciences, School of Medicine, The Johns Hopkins University, Baltimore, Maryland.
- James C. Hogg, M.D., Ph.D., Emeritus Professor of Pathology, Department of Pathology and Laboratory Medicine, University of British Columbia, Vancouver, British Columbia, Canada.
- V. Michael Holers, M.D., Head, Division of Rheumatology; Professor of Medicine and Immunology, University of Colorado School of Medicine, Denver, Colorado.
- Stephen T. Holgate M.D., Professor, Fellow of the Academy of Medical Sciences, Medical Research Council, Clinical Professor of Immunopharmacology, University of Southampton, United Kingdom.
- Philip P. Huang, M.D., M.P.H., Medical Director, Health Authority, Austin, Travis County Health and Human Services Department, Austin, Texas.
- Yvonne Hunt, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Richard D. Hurt, M.D., Professor of Medicine, College of Medicine, Director, Nicotine Dependence Center, Mayo Clinic, Rochester, Minnesota.
- Corrine Husten, M.D., M.P.H., Senior Medical Advisor, Center for Tobacco Products, Food and Drug Administration, Rockville, Maryland.
- Andrew Hyland, Ph.D., Chair, Department of Health Behavior, Roswell Park Cancer Institute, Buffalo, New York.
- Eric J. Jacobs, Ph.D., Strategic Director of Pharmacoepidemiology, Epidemiology Research Program, American Cancer Society, Atlanta, Georgia.
- Prabhat Jha, O.C., M.D., D.Phil., Professor and Chair in Disease Control, University of Toronto, Executive Director, Centre for Global Health Research, St. Michael's Hospital, University of Toronto, Ontario, Canada.
- Kenneth C. Johnson, Ph.D., Senior Epidemiologist/Research Scientist, Centre for Chronic Disease, Prevention and Control, Public Health Agency of Canada, Ottawa, Ontario, Canada.
- Ron Johnson, Ph.D., Program Director, Cancer Etiology Branch, Division of Cancer Biology, National Cancer Institute, Rockville, Maryland.
- Amy E. Kalkbrenner, Ph.D., M.P.H., Assistant Professor, Zilber School of Public Health, University of Wisconsin-Milwaukee, Milwaukee, Wisconsin.
- Gilaad G. Kaplan, M.D., M.P.H., Associate Professor, Departments of Medicine and Community Health Sciences, Division of Gastroenterology, University of Calgary, Calgary, Alberta, Canada.
- Annette Kaufman, Ph.D., M.P.H., Health Scientist/Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Talmadge E. King, Jr., M.D., Chair, Department of Medicine, Julius R. Krevans Distinguished Professorship in Internal Medicine, Department of Medicine, University of California, San Francisco, California.
- Barbara B. E. Klein, M.D., M.P.H., Professor, School of Ophthalmology and Visual Sciences, University of Wisconsin, Madison, Wisconsin.
- Ronald Klein, M.D., M.P.H., Professor, Department of Ophthalmology and Visual Sciences, School of Medicine and Public Health, University of Wisconsin, Madison, Wisconsin.
- Jennie Kline, Ph.D., Senior Research Scientist, Imprints Center, New York State Psychiatric Institute, New York, New York; Adjunct Professor of Epidemiology, Department of Epidemiology at Mailman School of Public Health and the Sergievsky Center, Columbia University, New York, New York.
- Nino Künzli, M.D., Ph.D., Deputy Director and Head of Department, Swiss Tropical and Public Health Institute, Basel, Switzerland; Professor, Department of Public Health, University of Basel, Basel, Switzerland.
- Stephanie Land, Ph.D., Statistician, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Kate Langley, Ph.D., Research Associate, The Medical Research Council Centre for Neuropsychiatric Genetics and Genomics, Neuroscience and Mental Health Research Institute, Cardiff University, Cardiff, United Kingdom.
- Scott J. Leischow, Ph.D., Department of Health Sciences Research, Mayo Clinic, Scottsdale, Arizona.
- Edward V. Loftus, Jr., M.D., Consultant, Division of Gastroenterology and Hepatology, Director of Inflammatory Bowel Disease Interest Group, Professor of Medicine, Mayo Clinic, Rochester, Minnesota.
- David A. Lomas, Ph.D., Sc.D., F.R.C.P., FMedSci., Dean, Faculty of Medical Sciences, University College London, London, United Kingdom.
- Jay H. Lubin, Ph.D., Special Volunteer, Biostatistics Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Rockville, Maryland.
- Russell V. Luepker, M.D., M.S., Mayo Professor, Division of Epidemiology and Community Health, School of Public Health, University of Minnesota, Minneapolis, Minnesota.
- Jing Ma, M.D., Ph.D., Associate Professor, Channing Division of Network Medicine, Brigham and Women's Hospital, Harvard Medical School; Department of Epidemiology, Harvard School of Public Health, Harvard University, Boston, Massachusetts.
- Patricia L. Mabry, Ph.D., Senior Advisor and Acting Deputy Director, Office of Behavioral and Social Sciences Research, Office of the Director, National Institutes of Health, Bethesda, Maryland.
- Judith Mackay, F.R.C.P (Edin), F.R.C.P (Lon), Senior Advisor, World Lung Foundation, New York, USA; Director, Asian Consultancy on Tobacco Control, Hong Kong.
- Ruth E. Malone, R.N., Ph.D., F.A.A.N., Professor and Chair, Department of Social and Behavioral Sciences, School of Nursing, University of California, San Francisco, Editor, Tobacco Control, San Francisco, California.
- Stephen E. Marcus, Ph.D., Epidemiologist and Program Director, Social and Behavioral Modeling Research Program, Division of Biomedical Technology, Bioinformatics, and Computational Biology, National Institute of General Medical Sciences, National Institutes of Health, Bethesda, Maryland.
- Joseph B. Margolick, M.D., Ph.D., Professor, Department of Molecular Microbiology and Immunology, Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.
- Fernando J. Martinez, M.D., M.S., Professor of Internal Medicine, Associate Division Chief of Clinical Research, Division of Pulmonary and Critical Care Medicine, University of Michigan, Ann Arbor, Michigan.
- Carol A. Mathews, M.D., Associate Professor, Department of Psychiatry, University of California, San Francisco; Co-Chair Tourette Syndrome Association International Consortium for Genetics, San Francisco, California.
- J. Michael McGinnis, M.D., M.A., M.P.P., Executive Director, Value and Science-Driven Health Care; Senior Scholar, Institute of Medicine, The National Academies, Washington, D.C.
- Paul Melstrom, Pharm.D., Ph.D., Toxicologist/Epidemiologist, Epidemiology Branch, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Martin M. Miner, M.D., Co-Director, Men's Health Center, The Miriam Hospital, Clinical Associate Professor of Family Medicine and Urology, Warren Alpert School of Medicine, Brown University, Providence, Rhode Island.
- Glen Morgan, Ph.D., Psychologist, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Matthew L. Myers, J.D., President, Campaign for Tobacco-Free Kids, Washington, D.C.
- Thomas E. Novotny, M.D., M.P.H., Professor and Associate Director for Border and Global Health, Division of Epidemiology, Graduate School of Public Health, San Diego State University, San Diego, California.
- Sarah Nyante, Ph.D., M.S.P.H, Postdoctoral Fellow, Hormonal and Reproductive Epidemiology Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Rockville, Maryland.
- Andrew F. Olshan, Ph.D., Professor and Chair, Department of Epidemiology, Gillings School of Global Public Health, University of North Carolina, Chapel Hill, North Carolina.
- Jamie S. Ostroff, Ph.D., Chief, Behavioral Sciences Service, Department of Psychiatry and Behavioral Sciences, Memorial Sloan-Kettering Cancer Center; Professor of Psychology and Public Health, Weill Cornell Medical College, New York, New York.
- Yikyung Park, Sc.D., Staff Scientist, Nutritional Epidemiology Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Rockville, Maryland.
- John P. Pierce, Ph.D., Professor of Cancer Research, Department of Family and Preventive Medicine, Director of Population Research, Moores Cancer Center, University of California San Diego, La Jolla California.
- Elizabeth A. Platz, Sc.D., M.P.H., Professor, Department of Epidemiology, Johns Hopkins Bloomberg School of Public Health and the Sidney Kimmel Comprehensive Cancer Center, Johns Hopkins University, Baltimore, Maryland.
- Robert N. Proctor, Ph.D., Professor of the History of Science and Professor, by courtesy, of Pulmonary and Critical Care, Stanford University, Stanford, California.
- Stephen I. Rennard, M.D., Larson Professor, Division of Pulmonary, Critical Care, Allergy and Sleep Medicine, University of Nebraska Medical Center, Omaha, Nebraska.
- William N. Rom, M.D., M.P.H., Director, Division of Pulmonary, Critical Care, and Sleep Medicine, Sol and Judith Bergstein Professor of Medicine and Environmental Medicine, New York University School of Medicine, New York, New York.
- Julia H. Rowland, Ph.D., Director, Office of Cancer Survivorship, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Marc B. Schenker, M.D., M.P.H., Director, Center for Occupational and Environmental Health; Professor, Department of Public Health Sciences, University of California, Davis, California.
- Steven A. Schroeder, M.D., Distinguished Professor of Health and Healthcare and Director, Smoking Cessation Leadership Center, Department of Medicine, University of California-San Francisco, San Francisco, California.
- David A. Schwartz, M.D., Professor of Medicine and Immunology, Chair, Department of Medicine, University of Colorado, Aurora, Colorado.
- Donald W. Sexton, M.B.A., M.H.A., Doctoral Student, University of Michigan School of Public Health, and United States Army Medical Department, Ann Arbor, Michigan.
- A. Richey Sharrett, M.D., Dr. P.H., Professor, Department of Epidemiology, Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.
- Peter G. Shields, M.D., Deputy Director, Comprehensive Cancer Center, Professor, College of Medicine, James Cancer Hospital, The Ohio State University Wexner Medical Center, Columbus, Ohio.
- Donald R. Shopland, U.S. Public Health Service (retired), Ringgold, Georgia.
- Alfred Sommer, M.D., M.H.S., Dean Emeritus, Bloomberg School of Public Health; Professor, Departments of Epidemiology, Ophthalmology and International Health, Johns Hopkins University, Baltimore, Maryland.
- Frank E. Speizer, M.D., E. H. Kass Distinguished Professor of Medicine, Harvard Medical School, Channing Laboratory, Department of Medicine, Brigham and Women's Hospital, Boston, Massachusetts.
- Meir J. Stampfer, M.D., Dr.P.H., Head, Chronic Disease Epidemiology Unit, Channing Division of Network Medicine, Department of Medicine, Brigham and Women's Hospital and Harvard Medical School; Professor of Epidemiology and Nutrition, Harvard School of Public Health; and Professor of Medicine, Harvard Medical School, Boston, Massachusetts.
- Gary D. Stoner, Ph.D., Professor, Department of Medicine, Division of Hematology and Oncology, Medical College of Wisconsin, Milwaukee, Wisconsin.
- Catherine M. Stoney, Ph.D., Program Director, Division of Cardiovascular Sciences, National Heart, Lung, and Blood Institute, National Institutes of Health, Bethesda, Maryland.
- Ira B. Tager, M.D., M.P.H., Professor Emeritus of Epidemiology, School of Public Health, University of California, Berkeley, California.
- Prue Talbot, Ph.D., Professor of Cell Biology, Director of the Stem Cell Center and Core, Department of Cell Biology and Neuroscience, University of California, Riverside, California.
- Crystal E. Tan, M.D., M.S., Center for Tobacco Control Research and Education, University of California, San Francisco, California.
- Michael J. Thun, M.D., M.S., Emeritus Vice President, Epidemiology and Surveillance Research, American Cancer Society, Atlanta, Georgia.
- Douglas Tipperman, M.S.W., Lead Public Health Advisor, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.
- Benjamin Toll, Ph.D., Program Director, Smoking Cessation Service at Smilow Cancer Hospital and Yale Cancer Center; Associate Professor, Department of Psychiatry, School of Medicine, Yale University, New Haven, Connecticut.
- Edward J. Trapido, Sc.D., F.A.C.E., Associate Dean for Research, Professor and Wendell H. Gauthier Chair of Cancer Epidemiology, Louisiana State University School of Public Health; Deputy Director, Stanley S. Scott Cancer Center; Professor of Medicine and Senior Liaison to the Dean of the School of Medicine, Louisiana State University Health Sciences Center, New Orleans, Louisiana.
- Bruce J. Trock, Ph.D., Professor, Departments of Urology, Oncology, Epidemiology, and Environmental Health Sciences, Director, Division of Epidemiology of the James Buchanan Brady Urological Institute, Johns Hopkins School of Medicine, Baltimore, Maryland.
- Donna Vallone, Ph.D., M.P.H., Senior Vice President, American Legacy Foundation; Assistant Professor (Adjunct), Department of Health, Behavior and Society, Johns Hopkins Bloomberg School of Public Health, Baltimore, Maryland.
- Rohit Varma, M.D., M.P.H., Professor and Chair, Illinois Eye and Ear Infirmary, Department of Ophthalmology and Visual Sciences; Associate Dean for Strategic Planning, College of Medicine, Chicago, Illinois.
- Robert E. Vollinger, M.S.P.H., Public Health Advisor, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.
- Melanie A. Wakefield, Ph.D., Director, Center for Behavioral Research in Cancer, Cancer Council Victoria, Melbourne, Australia.
- Robert B. Wallace, M.D., M.Sc., Director, Center on Aging, Professor, Department of Epidemiology, College of Public Health, and Professor, Department of Internal Medicine, Carver College of Medicine, University of Iowa, Iowa City, Iowa.
- Kenneth E. Warner, Ph.D., Avedis Donabedian Distinguished University Professor of Public Health, Department of Health Management and Policy, School of Public Health, University of Michigan, Ann Arbor, Michigan.
- Walter C. Willett, M.D., Dr. P.H., Departments of Nutrition and Epidemiology, Harvard School of Public Health, Channing Division of Network Medicine, Department of Medicine, Brigham and Women's Hospital and Harvard Medical School, Boston, Massachusetts.
- Nick Wilson, M.B.Ch.B., M.P.H., Associate Professor of Public Health, Co-Director of the Burden of Disease Epidemiology, Equity and Cost-effectiveness Programme, University of Otago, Wellington, New Zealand.
- Gayle C. Windham, Ph.D., M.S.P.H., Chief, Epidemiological Surveillance Unit, Division of Environmental and Occupational Disease, California Department of Public Health, Richmond, California.
- Anna H. Wu, Ph.D., Professor, Keck School of Medicine, Department of Preventive Medicine, University of Southern California, Los Angeles, California.
- Mandi Yu, Ph.D., M.S., Mathematical Statistician, Data Analysis and Interpretation Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, Rockville, Maryland.

## Other contributors were

- Julie M. Carter, M.P.H., Public Health Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Stephanie Denkhoff Boone, Ph.D., M.P.H., Postdoctoral Associate, Department of Epidemiology and Population Health, School of Public Health and Information Sciences, James Graham Brown Cancer Center, University of Louisville, Louisville, Kentucky.
- Athena Foong, M.S., Research Writer/Research Assistant to Jonathan M. Samet, M.D., M.S., Department of Preventive Medicine, Keck School of Medicine, University of Southern California, Los Angeles, California.
- Earl S. Ford, M.D., M.P.H., Medical Officer, Epidemiology and Surveillance Branch, Division of Population Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Joseph Gfroerer, Chief, Population Survey Branch, Division of Surveillance and Data Collection, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, U.S. Department of Health and Human Services, Rockville, Maryland.
- Beth Han, M.D., Ph.D., M.P.H., Statistician, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration, U.S. Department of Health and Human Services, Rockville, Maryland.
- S. Jane Henley, M.S.P.H., Epidemiologist, Division of Cancer Prevention and Control, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Carissa Baker Holmes, M.P.H., Public Health Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Lynn A. Hughley, Health Communications Specialist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Joel London, M.P.H., C.H.E.S., Health Communications Specialist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Kristy Marynak, M.P.P., Public Health Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Luz M. Moncayo, Executive Assistant to Jonathan M. Samet, M.D., M.S., Department of Preventive Medicine, Keck School of Medicine, Institute for Global Health, University of Southern California, Los Angeles, California.
- Jake Nikota, Ph.D. Candidate, Department of Pathology and Molecular Medicine, McMaster Immunology Research Centre, McMaster University, Hamilton, Ontario, Canada.
- Erin L. O'Connor, M.S., Data Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Alissa O'Halloran, M.S.P.H., Health Research Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Gabbi Promoff, M.A., Associate Director for Policy, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Hilda Razzaghi, Ph.D., M.S.P.H., Epidemiologist-ORISE Fellow, Birth Defects Branch, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Lisa C. Richardson, M.D., M.P.H., Associate Director for Science, Division of Cancer Prevention and Control, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Emily Ridgway, M.P.H., ORISE Fellow, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Lauren K. Shaw, M.S., Statistician, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Dana Shelton, M.P.H., Deputy Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Kathryn E. Szynal, Editorial Assistant, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Cheryll C. Thomas, M.S.P.H., Deputy Associate Director for Science, Office of the Director, Division of Cancer Prevention and Control, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Dale J. Willett, J.D., Candidate Class of 2013, Legal Research and Writing Assistant, Northeastern University School of Law, Boston, Massachusetts.
- Dongyan Yang, M.D., M.S., Assistant Professor, Department of Epidemiology and Population Health, School of Public Health, University of Louisville, Louisville, Kentucky.