# Definitions and Alternative Nomenclature of Genetic Symbols Used in This Report

Throughout this report, genes are represented by their abbreviations in italics. In many cases, proteins and enzymes related to these genes have the same abbreviation, presented in roman type. Definitions, alternative genetic symbols, related proteins and enzymes, and polymorphisms and variant genotypes are listed alphabetically by gene abbreviation.

Gene symbol used in this report | Definition | Alternative gene symbol | Related protein/enzyme | Polymorphism/variant genotype
AAT | α1-antitrypsin | SERPINA1 | AAT | PI*S, PI*Z, PI MZ, PI 22, GLN6VAL (S), GLN6LYS (Z)
ADD | adducin 1 (alpha) | ADD1 | ADD1 | GLY460TRP
AGT | O^6^-alkylguanine–DNA alkyltransferase | | AGT | ILE143VAL, GLY160ARG
AHR | aryl hydrocarbon receptor | | AHR
AHRR | aryl-hydrocarbon receptor repressor | | AHRR
AIB1 | amplified in breast 1 | NCOA3 | AIB1
AKT | v-akt murine thymoma viral oncogene homolog 1 | | AKT
ATM | ataxia telangiectasia mutated | | ATM
APC | adenomatous polyposis coli | | APC
APO2 | tumor necrosis factor receptor superfamily, member 10a | | APO2
APOE | apolipoprotein E | TNFRSF10A | APOE | *2
ARMS2 | age-related maculopathy susceptibility 2 | LOC387715 A69S | ARMS2 | rs10490942, rs10490912, rs10490924
BAD | BCL2-associated agonist of cell death | BBC2, BCL2L8 | BAD
BAX | BCL2-associated X protein | BCL2L4 | BAX
BCL3 | B-cell CLL/lymphoma 3 | | BCL3
BCL2L8 | BCL2-associated agonist of cell death | BAD | BCL2L8
BCL2L4 | BCL2-associated X protein | BAX | BCL2L4
BHLHB5 | basic helix-loop-helix family, member e22 | BHLHE22 | BHE22
BHLHE22 | basic helix-loop-helix family, member e22 | BHLHB5 | BHLHB5
BICD1 | bicaudal D homolog 1 (Drosophila) | | BICD1
BMP4 T538C | bone morphogenetic protein 4 | | BMP4
BOLL | bol, boule-like | | BOLL
BRCA1 | breast cancer 1, early onset | | BRCA1
BRCA2 | breast cancer 2, early onset | BRCC2 | BRCA2 | HIS372ASN (T27113G), ILE3412VAL (G93268A
BRCC2 | breast cancer 2, early onset | BRCA2 | BRCC2
BRMS1 | breast cancer metastasis suppressor 1 | | BRMS1
C3 | complement component 3 (C3) | | C3 | R102G, rs1047286, rs11569536, rs3745565, P314L
C7 | complement component 7 | CXCL10 | C7
CARD15 | nucleotide-binding oligomerization domain containing 2 | NOD2 | CARD15
CC2 | complement component 2 | | CC2
CDKN2A | cyclin-dependent kinase inhibitor 2A | P16 | CDKN2A
CFB | complement factor B | | CFB
CFH | complement factor H | | CFH | rs3753394, rs800292, rs1061147, rs1061170, rs380390, rs1329428, Y402H, rs1410996, rs2274700, T1277C, CAATTTAG (P1), CGGCTTAG (P2), rs1410996-AG, rs1410996-GG, (GG)rs10490924/(TT), (TT)rs10490924/(CC), Y402H, YY, AA, CC, TT, CT, HH
CHRNA3 | cholinergic receptor, nicotinic, α3 | | CHRNA3
CHRNA5 | cholinergic receptor, nicotinic, α5 | | CHRNA5
CHRNB4 | cholinergic receptor, nicotinic, β4 | | CHRNB4
COX2 | mitochondrially encoded cytochrome c oxidase II | | COX2
CRP | C-reactive protein | | CRP
CXCL10 | chemokine (C-X-C motif) ligand 10 | C7 | CXCL10
CYP17 | cytochrome P450, family 17, subfamily A, polypeptide 1 | CYP17A1 | CYP17
CYP1A1 | cytochrome P-450, family 1, subfamily A, polypeptide 1 (CYP1A1) | | CYP1A1 | *2A, *2C, m1/m2, *1, *2, MSPI
CYP1A2 | cytochrome P-450, family 1, subfamily A, polypeptide 1 | | CYP1A1
CYP1B1 | cytochrome P450, family 1, subfamily B, polypeptide 1 | | CYP1B1 | LEU/LEU, VAL/VAL, 119S
CYP2A6 | cytochrome P-450, family 2, subfamily A, polypeptide 6 | | CYP2A6
CYP2E1 | cytochrome P450, family 2, subfamily E, polypeptide 1 | | CYP2E1 | RSAI
DAT1 | dopamine active transporter 1 | SLC6A3 | DAT1 | +/+
DCC | deleted in colorectal carcinoma | | DCC
EGFR | epidermal growth factor receptor (erythroblastic leukemia viral (v-erb-b) onco homolog, avian) | | EGFR
ELN | Elastin | | ELN
ELOVL4 | ELOVL fatty acid elongase 4 | | ELOVL4
ENOS | endothelial nitric oxide synthase | NOS3 | ENOS, NOS3
EPHB2 | EPH receptor B2 | ERK | EPHB2
EPHX | epoxide hydrolase | | EPHX
EPHX1 | epoxide hydrolase 1, microsomal (xenobiotic) | | EPHX1
ERBB2 | v-erb-b2 avian erythroblastic leukemia viral oncogene homolog 2 | HER2 | ERBB2
ERCC2 | excision repair cross-complementing rodent repair deficiency, complementation group 2 | XPD | ERCC2
ERCC4 | excision repair cross-complementing rodent repair deficiency, complementation group 4 | XPF | ERCC4
ERCC5 | excision repair cross-complementing rodent repair deficiency, complementation group 5 | XPG | ERCC5
ERCC6 | excision repair cross-complementing rodent repair deficiency, complementation group 6 | | ERCC6
ERK | extracellular signal-regulated kinase | EPHB2 | ERK
ESR1 | estrogen receptor 1 | | ESR1
FAM13A | family with sequence similarity 13, member A | | FAM13A
FBLN5 | fibulin 5 | | FBLN5
FBXW7 | F-box and WD repeat domain containing 7, E3 ubiquitin protein ligase | | FBXW7
FUT2 | fucosyltransferase 2 (secretor status included) | SE | FUT2
GADD45 | growth arrest and DNA-damage-inducible, alpha | | GADD45
GFI1 | growth factor independent 1 transcription repressor | | GFI1
GST | glutathione-S-transferase | | GST
GSTA1 | glutathione S-transferase alpha 1 | | GSTA1
GSTA4 | glutathione-S-transferase α4 | | GSTA4
GSTM1 | glutathione-S-transferase μ1 (GSTM1) | GSTM1-1 | GSTM1 | A/B
GSTM3 | glutathione S-transferase μ3 (brain) | | GSTM3
GSTP1 | glutathione S-transferase π1 | | GSTP1
GSTT1 | glutathione-S-transferase θ1 (GSTT1) | GSTT1-1 | GSTT1 | DEL
HER2 | human epidermal growth factor receptor 2 | ERBB2 | HER2
HHIP | hedgehog interacting protein | | HHIP
HIF1A | hypoxia inducible factor 1, alpha subunit (basic helix-loop-helix transcription factor) | | HIF1A
HLA | major histocompatibility complex | HLA-A | HLA | SE
HLA-DPB1 | major histocompatibility complex, class II, DP beta 1 | | HLA-DPB1
HLA-DPB2 | major histocompatibility complex, class II, DP beta 2 (pseudogene) | | HLA-DPB2
HO-1 | heme oxygenase (decycling) 1 | HMOX1 | HMOX1
HRAS | v-Ha-ras Harvey rat sarcoma viral oncogene homolog | C-HRAS | C-HRAS, HRAS1 proto-oncoprotein
HTRA1 | HtrA (high temperature requirement factor A) serine peptidase 1 | | HTRA1 | GG, rs11200638, AA
IBD1 | nucleotide-binding oligomerization domain containing 2 | | IBD1
ICAM-1 | intercellular adhesion molecule 1 | | ICAM-1 | GLY241ARG
IGHMP2 | immunoglobulin mu binding protein 2 | | IGHMP2
IKKβ | inhibitor of kappa light polypeptide gene enhancer in B-cells, kinase beta | | IKK
IL-1β | interleukin-1β (IL-1β) | | IL-1β
IL-12 | | | IL-12
IL-13 | interleukin-13 | | IL-13
IL-4 | interleukin-4 | | IL-4
IL-5 | interleukin-5 | | IL-5
IL-6 | interleukin-6 | | IL-6
IL-8 | interleukin-8 | | IL-8
IL-10 | interleukin-10 | | IL-10
IL-17A | interleukin -17A | | IL-17A
IL-18 | interleukin -18 | | IL-18
IL-23 | interleukin -23 | | IL-23
IL-33 | interleukin -33 | | IL-33
IP-10 | chemokine (C-X-C motif) ligand 10 | C-7, CXCL10 | CXL 10
IREB2 | iron-responsive element binding protein 2 | | IREB2
IRF6 | interferon regulatory factor 6 | | IRF6
JNK-1 | c-Jun N-terminal kinase 1 | MAPK8 | JNK-1
KRAS | K-ras (v-Ki-ras2 Kirsten rat sarcoma viral oncogene homolog) | | KRAS
LacZ | beta-galactosidase | | LACZ
LC3B | microtubule-associated protein 1 light chain 3 beta | | LCB3
LGALS4 | lectin, galactoside-binding, soluble, 4 | | LGALS4
LIG4 | ligase IV, DNA, ATP-dependent | | LIG4
LOC387715 A69S | age-related maculopathy susceptibility 2 | ARMS2 | LOC387715 | GG, GT+TT, rs10490924, rs10490942
MAOA | monoamine oxidase A | | MAOA | 5′uVNTR
MAPK8 | mitogen-activated protein kinase 8 | JNK-1 | MK08
mEH3 | microsomal epoxide hydrolase (mEH) polymorphism in exon 3 | | mEH3
MEK | mitogen-activated protein kinase | | MEK
MGMT | O^6^-methylguanine-DNA methyltransferase | | MGMT | LEU84PHE, ILE143VAL
MnSOD2 | manganese superoxide dismutase 2 | | MnSOD2 | VAL (wild type), ALA
MMP | matrix metallopeptidase | | MMP
MMP 9 | matrix metallopeptidase 9 (gelatinase B, 92kDa gelatinase, 92kDa type IV collagenase) | | MMP 9
MMP 12 | matrix metallopeptidase 12 (macrophage elastase) | | MMP 12
MPO | myeloperoxidase | | MPO
MYH9 | myosin, heavy chain 9, non-muscle | | MYH9
MSX1 | muscle segment homeobox 1 | | MSX1 | CA, X1.1, X1.3, X2.1, X2.4, T2090G
MTHFR | methylenetetrahydrofolate reductase | | MTHFR | 677C→T, CC
NAT1 | N-acetyltransferase 1 | | NAT1, ARY1 | 1088, 1095, AA vs. TT, AA vs. CC, T1095A, 1088A, 1088T→A, 1095C→A
NAT2 | N-acetyltransferase 2 | | NAT2, ARY2 | _SNP2, 282C→T, 341T→C, 481T→C, 590G→A, 857G→A, *4, *5, *6, *7, *12, *13, *14, rs9987109, rs1208
NCOA3 | nuclear receptor coactivator 3 | AIB1 | NCOA3
NOD2 | nucleotide-binding oligomerization domain containing 2 | CARD15 | NOD2
NOS3 | nitric oxide synthase 3 (endothelial cell) | ENOS | ENOS, NOS3 | A(-922)G, SNP2, GLU298ASP, G894T
NOTCH1 | notch1 | | NOTCH1
NPPA | natriuretic peptide A | | NPAA | 2238T→C
P16 | cyclin-dependent kinase inhibitor 2A | CDKN2A | P16
P53 | tumor suppressor | | P53
PI | glutathione S-transferase pi 1 | SERPINA1 | | S, Z, ZZ
PI7 | polymerase (DNA directed), epsilon 3, accessory subunit | POLE3 | P17
PIK3CA | phosphatidylinositol-4,5-bisphosphate 3-kinase, catalytic subunit alpha | | PIK3CA
polA | polymerase (DNA directed), alpha 1, catalytic subunit | POLA1 | POLA
PTPN22 | protein tyrosine phosphatase, non-receptor type 22 | | PTPN22
RAD23B | RAD23 homolog B (S. cerevisiae) | | RAD23B
RAF | rapidly accelerated fibrosarcoma | | RAF
Rag1 | recombination activating gene 1 | | Rag1
RAS | rat sarcoma | | RAS
RASSF1A | Ras association (RalGDS/AF-6) domain family member 1 (A isoform) | | RASSF1A
RUNX1 | runt-related transcription factor 1 | | RUNX1
SE | fucosyltransferase 2 | FUT2 | SE | Rs4646903
SERPINA1 | serpin peptidase inhibitor, clade A (α-1 antiproteinase, antitrypsin), member 1 | AAT | SERPINA1 | PI*Z, SZ
SERPINE2 | serpin peptidase hihibotir, clade E (nexin, plasminogen activator inhibitor type 2), member 2 | PI7 | SERPINE2
SERPINA3 | serpin peptidase inhibitor, clade A (α-1 antiproteinase, antitrypsin), member 3 | | SERPINA3
SOD2 | superoxide dismutase 2 | | SOD2
SOX5 | SRY (sex determining region Y)-box 5 | | SOX5
STK11 | serine/threonine protein kinase 11 | | STK11
SULT | sulfotransferase | | SULT
SULT1A1 | sulfotransferase family, cytosolic, 1A, phenol-preferring, member 1 | | SULT1L1 | ARG/HIS, *HIS
TGF-α | transforming growth factor-α | | TGF- | TAQ1
TNFα | tumor necrosis factor (TNF superfamily, member 2) α | | TNFα
TGF-β | transforming growth factor-β | | TGF-β
TGF-β3 | transforming growth factor-β3 | | TGF-β3 | CA, x5.1, 5′UTR.1, T-24in4C, C641A, G15572
TNFRSF10A | tumor necrosis factor receptor superfamily, member 10a | | TNFRSF10A
TNFRSF10C | tumor necrosis factor receptor superfamily, member 10c, decoy without an intracellular domain | | TNFRSF10C
TP53 | tumor protein 53 | | TP53
TP63 | tumor protein 63 | | TP63
TRPA1 | transient receptor potential cation channel, subfamily A, member 1 | | TRPA1
UGT1A7 | UDP glucuronosyltransferase 1 family, polypeptide A7 | | UGT1A7 | SNP1
VEGF | vascular endothelian growth factor | VEGFA | VEGF
XPC | xeroderma pigmentosum, complementation group C | | XPC
XPD | xeroderma pigmentosum. Complementation group D | ERCC2 | XPD | LYS751GLN, GLN/GLN
XPF | xeroderma pigmentosum, complementation group F | ERCC4 | XPF
XPG | xeroderma pigmentosum, complementation group G | ERCC5 | XPG
XRCC1 | x-ray repair complementing defective repair in Chinese hamster cells 1 | | XRCC1 | ARG399GLN, ARG213HIS, ARG194TRP, ARG280HIS, C26602T, GLN632GLN, 194 ARG/ARG
XRCC2 | x-ray repair complementing defective repair in Chinese hamster cells 2 | | XRCC2
XRCC3 | x-ray repair complementing defective repair in Chinese hamster cells 3 | | XRCC3
XRCC5 | x-ray repair complementing defective repair in Chinese hamster cells 5 | | XRCC5