# Patterns of Tobacco Use Among U.S. Youth, Young Adults, and Adults

## Introduction

In the United States, the widespread use of tobacco began more than a century ago, and the epidemic of tobacco-caused diseases and premature mortality associated with tobacco use has continued to the present day. The purpose of the current chapter is to document key patterns and trends in tobacco use in the United States among youth (12–17 years of age), young adults (18–25 years of age), and adults age 26 years of age or older. The chapter indicates overall progress in the United States, but describes the persistence of a high prevalence of tobacco use among segments of the population. Historically, reports of the Surgeon General have focused almost exclusively on cigarette smoking, but the shifting patterns of tobacco use have necessitated the consideration of other products, both those that are noncombustible and others that deliver nicotine. Accordingly, this chapter includes critical information about cigars and smokeless tobacco, and it highlights changing patterns of tobacco use. Information about new and emerging products, such as e-cigarettes, is also included. Clearly, the effective characterization of key patterns and trends in tobacco use is critical to the development and maintenance of programs designed to reduce the burden of tobacco-caused morbidity and mortality.

### Data Sources

In the United States, a variety of national surveillance systems collect tobacco-specific data for youth, young adults, and adults. These systems typically assess behaviors related to cigarette smoking and, sometimes, the use of other tobacco products; some also collect information on important aspects of tobacco use (e.g., quit attempts). These surveys have differing methods and provide comparable, but not identical, measures of tobacco use. Because each survey provides unique information, monitoring the results of all of them is necessary to fully understand behaviors and trends. The principal surveys used in this chapter are described in Appendix 13.1, and additional information about data sources for adolescents is available in the 2012 Surgeon General's report, Preventing Tobacco Use Among Youth and Young Adults (U.S. Department of Health and Human Services [USDHHS] 2012). For this chapter, specific national surveillance systems were selected to serve as primary data sources based on the salience of their content, the timeliness of their data, the completeness with which they cover the populations they are intended to represent, and the strength of their methodology.

In this chapter, cross-sectional data are presented from three national surveillance systems: Youth Risk Behavior Surveillance System (YRBSS), National Survey on Drug Use and Health (NSDUH), and National Health Interview Survey (NHIS). Each of these population-based systems uses anonymous or confidential self-reported surveys to gather data. Generally, self-reported data are considered to be sufficiently accurate for tracking the general pattern of tobacco use in populations (Brener et al. 2003; USDHHS 2004). Table 13.1 and Appendix 13.1 describe the three data sources in detail, and Appendix 13.2 defines the survey items and terms used in the present report.

Table 13.1 Sources of national survey data on tobacco use, United States

| NSDUH | National YRBS | NHIS
Sponsoring agency or organization | SAMHSA | CDC | CDC
Type of survey | Cross-sectional | Cross-sectional | Cross-sectional
Years | 2012 | 1991, 1993, 1995, 1997, 1999, 2001, 2003, 2005, 2007, 2009, and 2011 | 1965–2012 (various years)
Mode of survey administration | Audio computer-assisted self-administered personal interview | School-based, self-administered questionnaire | Computer-assisted personal interview
Response rate | 2012: 86.1% for household screening; 73.0% for interviewing | 2011: 81% for schools; 87% for students; 71% overall | 2010: 60.8% for household adults 2012: 61.2% for household adults
Sample size | 2012: 68,309 persons ≥12 years of age, including 45,836 adults ≥18 years of age | 2011: 15,425 9th–12th grade students | 2010: 27,157 adults ≥18 years of age 2012: 34,525 adults ≥18 years of age
Type of tobacco use examined | Cigarettes, smokeless tobacco (chewing tobacco, snuff), cigars, and pipe tobacco | Cigarettes, smokeless tobacco, and cigars | Cigarettes (annually), smokeless tobacco, and cigars (selected years)

Note: CDC = Centers for Disease Control and Prevention; NHIS = National Health Interview Survey; NSDUH = National Survey on Drug Use and Health; SAMHSA = Substance Abuse and Mental Health Services Administration; YRBS = National Youth Risk Behavior Survey.

YRBSS includes both state and local surveys and a national survey. The National Youth Risk Behavior Survey (YRBS) uses probability samples of public and private high school students who fill out questionnaires administered anonymously in schools. This survey is representative of the U.S. high school population. National YRBS data are available from 1991–2011 and are used in this report to illustrate trends over time. In contrast to YRBS, NSDUH, which is conducted under the direction of the federal Substance Abuse and Mental Health Services Administration (SAMHSA) employs household-based sampling, which is designed to represent the entire civilian, noninstitutionalized population of the United States from 12 years of age and older. A major strength of NSDUH is that the national sample is allocated equally across three age-specific population groups that were defined earlier in this chapter: youth, young adults, and adults. In addition, NSDUH includes youth who have dropped out of school or are frequently absent, which are two groups more likely to smoke. NSDUH is the only national surveillance system that has a wide repertoire of tobacco-use measures that can be compared across the three priority populations. Questionnaires for NSDUH are completed confidentially in the home with audio computer-assisted self-interviewing so that only the respondent is aware of the questions being asked. Unless otherwise indicated, all NSDUH data presented in this chapter are from the 2012 survey. Last, NHIS, which has been a primary source of health data on the U.S. adult population since the 1950s, is an annual cross-sectional household interview survey of the adult (18 years of age and older) U.S. civilian noninstitutionalized population. NHIS data on tobacco use are available for the period 1965–2011 and are used in this report to illustrate trends over time. In addition, data from NHIS were pooled into a combined dataset and analyzed to obtain estimates of changes in the patterns of use of cigarettes over time by gender, calendar year, and birth cohorts from 1890–1990 (Holford et al. in press).

### Key Epidemiologic Measures

This chapter covers a variety of epidemiologic measures, including the age when cigarette smoking begins, current prevalence of daily and intermittent cigarette smoking, indicators of smoking cessation, current prevalence of smokeless tobacco use and cigar smoking, and current prevalence of polytobacco use (i.e., the use of multiple tobacco products). Data from the survey or surveys best suited to address the issue were selected for presentation in the text and accompanying tables and figures. The most recent estimates (i.e., those for 2012) use data from NSDUH, while estimates of cessation indicators rely on data from NHIS. Trends over time among youth are based on data from the National YRBS, and trends over time among adults use data from NHIS. These trends are presented both as annual cross-sectional survey results and as pooled data across birth cohorts from annual surveys.

## Historical Trends in Tobacco Use

### Trends in Tobacco Use Consumption: 1900–2011

Numerous Surgeon General's reports have reviewed patterns of tobacco use in the twentieth century (USDHHS 1989, 1994, 1998, 2000, 2012). In the earliest decade of the last century, Americans consumed tobacco primarily in the form of chewing tobacco and cigars, but cigarette use grew rapidly after that period, increasing sharply between the 1910s and the mid-1960s, first in men and then in women (Figure 13.1) (USDHHS 2000). Additionally, during this period, tobacco users shifted away from chewing tobacco, inhaling snuff, and smoking cigars and pipes (USDHHS 2000; Giovino 2002) to the smoking of cigarettes. Although cigarette consumption has been declining since the mid-1960s, cigarettes remain by far the most commonly used tobacco product in the United States. In the context of declining cigarette consumption, however, the consumption of moist snuff, cigars, and pipe/roll-your-own tobacco slightly increased during the first decade of the twenty-first century (Figure 13.2).

Figure 13.1 Per capita consumption of different forms of tobacco in the United States, 1880–2011

Source: U.S. Department of Treasury 2012.

Stacked line graph indicates that from 1880 to the late teens of the 20 century, the most consumed tobacco products (as measured by pounds of tobacco per capita) in the United States were chewing tobacco, cigars, and pipe/roll your own tobacco. From that point through 2010, cigarettes consistently and clearly were the most consumed tobacco product. In the early 1950s, U.S. consumption of cigarettes peaked at more than 10 pounds of tobacco per capita per year. Starting in the 1960s, however, pounds of tobacco products consumed in the United States generally decreased through 2010 for all forms of tobacco, including snuff, chewing, pipe/roll your own, cigars, and cigarettes.

Figure 13.2 Per capita consumption of noncigarette products in the United States, 1970–2011

Source: U.S. Department of Treasury 2012.

Note: A “little cigar” is defined in the Federal Cigarette Labeling and Advertising Act of 1965 as “any roll of tobacco wrapped in leaf tobacco or any substance containing tobacco (other than any roll of tobacco which is a cigarette within the meaning of subsection (1)) and as to which one thousand units weigh not more than three pounds.”

Line graph shows trends in the per capita consumption of noncigarette products (cigars, little cigars, pipe/roll your own, chewing, and snuff) in the United States from 1970 to 2011. The United States consumed fewer pounds of cigars, pipe/roll your own tobacco, and chewing tobacco products per capita in 2011 than it did in 1970. However, pounds of snuff tobacco more than doubled between 1970 and 2011. U.S. consumption of little cigars remained relatively unchanged between 1970 and 2011.

### Changing Patterns in the Consumption of Tobacco Products Other Than Cigarettes, by Type

The increase in use of roll-your-own/pipe tobacco has largely been attributed to cigarette smokers seeking less expensive cigarettes (Stehr 2005). In fact, roll-your-own cigarettes are typically less expensive than factory-made cigarettes, and loose tobacco for roll-your-own cigarettes is often taxed at a lower rate than manufactured cigarettes at both the federal and state levels (Morris and Tynan 2012; Young et al. 2012).

#### Smokeless Tobacco

After decades of limited use of smokeless tobacco, consumption rose between 1970 and the mid-1980s because of aggressive marketing to youth and young adult males (National Cancer Institute [NCI] 1992; USDHHS 2000, 2012). From the mid-1980s to 2000, the overall consumption of smokeless tobacco (i.e., chew and moist snuff) declined. Although consumption of moist snuff increased rapidly between 1990 and 2011, decreases in chewing tobacco since the mid-1980s produced a net negative effect in the smokeless tobacco consumed until 2000 when growth in consumption of moist snuff contributed to a net increase in smokeless tobacco. This resulted in a consistent growth in total consumption of smokeless tobacco since 2004. The growth in moist snuff use came as both Reynolds American, Inc. and Altria Group, Inc., purchased the major smokeless tobacco companies in the United States (Conwood and U.S. Smokeless Tobacco Company, respectively) and launched smokeless tobacco products under the brand names of cigarettes (e.g., Camel Snus and Marlboro Snus) between 2006–2010. Factors found to contribute to the continued growth of moist snuff use include increased tobacco company expenditures to promote moist snuff use (Federal Trade Commission 2012), the initiation of snuff use among cigarette smokers (current or former) in the face of increasing cigarette prices and smoking bans, as well as the use of targeted marketing (Ohsfeldt et al. 1997; Delnevo et al. 2012). Indeed, advertising for some moist snuff products, often cobranded with cigarette names, has consistently included messages aimed explicitly at smokers and has positioned the products as modern and acceptable tobacco alternatives to use in places where smoking is banned or otherwise inconvenient (Delnevo et al. 2012).

#### Cigars

Cigars were a common form of tobacco use for much of the twentieth century, but after peaking around 1950, per capita consumption has shrunk dramatically (Figure 13.1). This measure reached its lowest level in 1993, but since then per capita consumption has more than tripled (U.S. Department of Agriculture 2007; U.S. Department of Treasury 2012). The increase in cigar consumption in the mid-1990s was attributed to large cigars, but as shown in Figure 13.3, which presents per capita consumption in “sticks” rather than pounds of tobacco (as shown in Figures 13.1 and 13.2), the rapid increase in the 2000s up to 2008 was primarily attributable to the consumption of small cigars, which resemble cigarettes (Delnevo 2006). Traditionally, cigar smoking in the United States was a behavior of older men (NCI 1998), but the industry's increased marketing of cigars to targeted groups such as youth, young adults, and women (NCI 1998) reversed the low rates of use typically seen among these groups. By the early 2000s, some surveys suggested that the cigar boom was over (Gilpin and Pierce 2001; Nyman et al. 2002), but consumption more than doubled from 2000–2012 (U.S. Department of Treasury 2012). In 2009, the reauthorization of the State Children's Health Insurance Program included an increase in the federal excise tax on various tobacco products, and while the new law closed some loopholes by equalizing the tax on little cigars with cigarettes, it created other exceptions that the tobacco industry was quick to exploit. Around that time, the industry slightly increased the weight of some of its cigar products, shifting them from the “little cigar” into the more favorable “cigar” category (over 3 pounds per 1,000 cigars) for tax classification purposes. This shift allowed for a lower retail price and the presentation of a new product on the market, the “filtered cigar,” which is slightly larger than the little cigar but is taxed as a large cigar (U.S. Department of Treasury 2012). Consumption of little cigars dropped significantly in 2009, but the total consumption of cigars continued to increase annually (Figure 13.3).

Figure 13.3 Cigar consumption in the United States, 2000–2012

Source: U.S. Department of Treasury 2012.

Note: A “little cigar” is defined in the Federal Cigarette Labeling and Advertising Act of 1965 as “any roll of tobacco wrapped in leaf tobacco or any substance containing tobacco (other than any roll of tobacco which is a cigarette within the meaning of subsection (1)) and as to which one thousand units weigh not more than three pounds.” FET = federal excise tax; S-CHIP = State Children's Health Insurance Program.

Mixed bar and line graph shows annual cigar consumption (in billions of sticks) in the United States from 2000 to 2012. Overall, consumption of large cigars rose each year, ultimately tripling in consumption from 2000 to 2012. Consumption of little cigars rose each year through 2008 and then decreased annually through 2012. By 2012, consumption of little cigars fell two-thirds from 2000. Of note, in 2009, the consumption of large cigars increased dramatically and little cigars fell sharply as a result of the State Children's Health Insurance Program equalizing the federal excise taxes on cigarettes and little cigars.

## Cigarette Smoking

### Age When Smoking Begins

One of the most important—and widely cited—findings from the 1994 and 2012 Surgeon General's reports on smoking and health was that virtually all cigarette smoking begins before 18 years of age (USDHHS 1994, 2012). An examination of the birth cohort data indicates that, historically speaking, this is true for males born after 1950 and for females born after 1960. Table 13.2, which uses 2012 NSDUH data in an analysis parallel to that conducted for the 1994 and 2012 Surgeon General's reports, further illustrates and updates this finding. In the 2012 NSDUH, adult smokers 30–39 years of age were asked about their first experience with cigarette smoking. Among adults who had ever smoked cigarettes daily, the mean age (in years) of smoking initiation was 15.3, and the mean age of beginning to smoke daily was 18.2. Among adults who had ever smoked cigarettes daily, 86.9% had tried their first cigarette by the time they were 18 years of age, while an additional 11.5% did so by 26 years of age. About two-thirds (64.3%) of adults who had ever smoked daily began to do so by 18 years of age, and almost one-third of adults who had ever smoked (22.7%) began to smoke daily between 18–26 years of age. Virtually no initiation of cigarette smoking (<1.5%) and few transitions to daily smoking (<4.3%) actually occurred in adulthood—that is, after 26 years of age. Of note, initiation of cigarette smoking often occurred early in adolescence (before 18 years of age); 13.6% of adults who had ever smoked daily began smoking by age 14, before entering high school.

Table 13.2 Cumulative percentages of recalled age at which a respondent who had ever smoked daily first used a cigarette and began smoking daily,^a^ by smoking status among adults (30–39 years of age); National Survey on Drug Use and Health 2012; United States

| Persons who had ever smoked daily
Recalled age (years) | First tried a cigarette % (95% CI) | Began smoking daily % (95% CI)
≤10 | 7.2 (6.01–8.54) | 1.2 (0.78–1.83)
≤11 | 10.4 (8.93–11.99) | 2.3 (1.63–3.21)
≤12 | 19.1 (17.33–21.10) | 4.6 (3.70–5.72)
≤13 | 29.6 (27.43–31.95) | 8.6 (7.37–9.97)
≤14 | 42.5 (40.07–44.91) | 13.6 (12.06–15.22)
≤15 | 58.0 (55.48–60.52) | 23.3 (21.12–25.53)
≤16 | 70.3 (67.96–72.61) | 36.4 (33.98–38.88)
≤17 | 77.3 (75.08–79.31) | 47.9 (45.44–50.43)
≤18 | 86.9 (85.09–88.58) | 64.3 (61.79–66.80)
≤19 | 90.3 (88.68–91.76) | 72.2 (69.75–74.48)
≤20 | 93.3 (91.97–94.41) | 79.2 (76.99–81.16)
≤21 | 95.3 (94.10–96.27) | 83.6 (81.58–85.48)
≤22 | 96.2 (95.01–97.04) | 86.7 (84.79–88.40)
≤23 | 96.8 (95.67–97.59) | 88.7 (86.83–90.30)
≤24 | 97.4 (96.33–98.11) | 90.3 (88.49–91.78)
≤25 | 98.1 (97.16–98.75) | 93.3 (91.74–94.53)
≤26 | 98.4 (97.46–99.00) | 94.9 (93.49–95.96)
≤27 | 99.0 (98.24–99.43) | 95.6 (94.31–96.65)
≤28 | 99.4 (98.85–99.69) | 96.3 (95.00–97.21)
≤29 | 99.5 (98.92–99.75) | 97.2 (96.09–98.03)
≤30 | 99.9 (99.64–99.96) | 99.2 (98.58–99.50)
≤31–39 | 100.0 | 100.0
Mean age (years) | 15.3 | 18.2

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval.

a Based on responses to the following questions: “Have you ever smoked part or all of a cigarette?” “How old were you the first time you smoked part or all of a cigarette?” “Has there ever been a period in your life when you smoked cigarettes every day for at least 30 days?” “How old were you when you first started smoking cigarettes every day?”

### Current Prevalence of Smoking

Current cigarette smoking is the measure most commonly used to describe the prevalence of cigarette smoking, but surveillance systems offer different definitions of current smoking (Delnevo and Bauer 2009). NHIS defines current smoking among adults as having smoked at least 100 cigarettes during one's lifetime and smoking every day or some days. NSDUH defines current smoking for youth, young adults, and adults as having smoked part or all of a cigarette during the past 30 days. Thus, SAMHSA does not use 100 lifetime cigarettes as a threshold when making estimates of the prevalence of current cigarette smoking from NSDUH data. This chapter continues to use the criterion of smoking part or all of a cigarette during the past 30 days for youth and young adults. To facilitate comparisons with NHIS, however, data in selected tables on all adults (18 years of age or older) incorporate the 100-cigarette threshold, as noted in the footnotes. Last, YRBSS defines current smoking for students as smoking on at least 1 day during the 30 days before the survey, but it does not require current smokers to have smoked at least 100 cigarettes in their lifetime (see Appendix 13.2).

#### Adolescents and Young Adults

According to the 2012 NSDUH survey, the prevalence of current cigarette smoking among youth 12–17 years of age (Table 13.3) was 6.6% and was similar among males (6.8%) and females (6.3%). By race or ethnicity, the prevalence was highest among White youth (8.2%). Current cigarette smoking increased with age among youth, with a rate of 1.2% for the youngest group (12–13 years of age) and 13.6% for the oldest (16–17 years of age). A higher prevalence of smoking was noted among youth living below the poverty level (7.6%) than in those living at or above this threshold (6.2%). Last, the prevalence was highest in the Midwest and South.

Table 13.3 Prevalence of current cigarette smoking^a^ among young people, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | 12–17 years of age % (95% CI) | 18–25 years of age % (95% CI)
Overall | 6.6 (6.1–7.0) | 31.8 (30.9–32.7)
Gender
Male | 6.8 (6.2–7.4) | 36.6 (35.3–37.9)
Female | 6.3 (5.8–6.9) | 27.1 (25.9–28.2)
Race/ethnicity
White, non-Hispanic | 8.2 (7.6–8.8) | 36.6 (35.4–37.8)
Male | 8.3 (7.5–9.2) | 40.6 (38.9–42.2)
Female | 8.1 (7.3–9.0) | 32.5 (30.9–34.2)
Black or African American, non-Hispanic | 4.1 (3.2–5.1) | 26.2 (24.1–28.4)
Male | 4.8 (3.6–6.3) | 30.9 (27.8–34.3)
Female | 3.3 (2.2–4.9) | 21.9 (19.1–24.9)
Hispanic or Latino | 4.8 (4.0–5.8) | 25.0 (23.1–27.0)
Male | 5.2 (4.1–6.6) | 30.9 (27.9–34.1)
Female | 4.4 (3.5–5.6) | 18.6 (16.5–20.9)
Other^b^ | 4.5 (3.5–5.8) | 26.4 (23.3–29.7)
Male | 4.4 (3.0–6.4) | 33.1 (28.3–38.3)
Female | 4.7 (3.4–6.4) | 20.0 (16.6–23.9)
Age (in years)
12–13 | 1.2 (0.9–1.5) | NA
14–15 | 4.6 (4.1–5.2) | NA
16–17 | 13.6 (12.6–14.6) | NA
18–20 | NA | 28.2 (26.8–29.7)
21–23 | NA | 33.8 (32.4–35.3)
24–25 | NA | 34.5 (32.7–36.2)
Poverty status
At or above poverty level | 6.2 (5.8–6.7) | 31.3 (30.2–32.3)
Below poverty level | 7.6 (6.7–8.7) | 34.3 (32.5–36.0)
Unknown^c^ | NA | 22.1 (15.9–29.8)
Region
Northeast | 5.7 (5.0–6.5) | 31.7 (29.7–33.8)
Midwest | 7.8 (7.0–8.6) | 35.6 (33.8–37.5)
South | 7.2 (6.4–8.0) | 32.4 (30.9–33.8)
West | 5.1 (4.3–6.0) | 27.7 (25.8–29.7)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval; NA = not applicable.

a Based on responses to the question “During the past 30 days, have you smoked part or all of a cigarette?” Respondents who chose “Yes” were classified as current smokers.

b Includes Asian, American Indian or Alaska Native, Native Hawaiian or Other Pacific Islander, and persons of 2 or more races.

c Respondents 18–22 years of age currently living in a college dormitory were included in the Unknown category.

Of the three age groups of interest in this chapter, young adults 18–25 years of age had the highest prevalence of current cigarette smoking (31.8% for this group vs. 6.6% for youth) (Table 13.3). Among young adults, prevalence was higher for males (36.6%) than for females (27.1%), and this pattern held for all racial/ethnic groups. Also among young adults, Whites had the highest prevalence of current smoking (36.6%), followed by Blacks (26.2%) and Hispanics (25.0%). When gender and race/ethnicity among young adults are combined, White males had the highest prevalence (40.6%) and Hispanic females the lowest (18.6%). Prevalence also varied by region, with the rate highest in the Midwest and lowest in the West. Although there was little variation in prevalence by age among young adults, the increase in prevalence from the oldest group among young people (16–17 years of age) to the youngest group among young adults (18–20 years of age) was dramatic—from 13.6% to 28.2%. Through its advertising and promotional campaigns, the tobacco industry markets heavily to its youngest legal target: young adults (Katz and Lavack 2002; Ling and Glantz 2002; Biener and Albers 2004); at 18 years of age, the purchase of cigarettes is legal in most states in the United States.

#### Adults

The 2012 prevalence of current cigarette smoking for all adults (i.e., those 18 years of age or older) was 22.0% according to NSDUH (Table 13.4). This estimate is higher than the 18.1% reported using NHIS in 2012 (Figure 13.4). Factors contributing to this difference and other differences between the two surveys are discussed in Appendix 13.2. Per the 2012 NSDUH, adult males had a higher prevalence (24.8%) of current smoking than adult females (19.3%). By race/ethnicity, prevalence was highest among American Indians/Alaska Natives, at 38.5%. The prevalence was similar for Whites (23.9%) and Blacks (22.6%) and lowest among Hispanics (15.2%) and Asians (8.3%). Males had a higher prevalence than females for all racial/ethnic groups other than American Indians/Alaska Natives for whom data are lacking. The differential by gender was most pronounced among Asians, where the ratio was about 3 (males) to 1 (female).

Table 13.4 Prevalence of current cigarette smoking^a^ among adults 18 years of age and older, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | Male % (95% CI) | Female % (95% CI) | Total % (95% CI)
Total | 24.8 (23.9–25.7) | 19.3 (18.5–20.2) | 22.0 (21.3–22.6)
Race/ethnicity
White, non-Hispanic | 25.6 (24.5–26.8) | 22.2 (21.1–23.3) | 23.9 (23.0–24.7)
Black, non-Hispanic | 28.9 (25.9–32.0) | 17.4 (15.2–19.8) | 22.6 (20.6–24.6)
Hispanic | 19.2 (17.1–21.6) | 11.2 (9.7–12.9) | 15.2 (13.8–16.7)
American Indian/Alaska Native, non-Hispanic | –^b^ | –^b^ | 38.5 (30.6–47.2)
Asian, non-Hispanic | 13.1 (9.3–18.2) | 4.3 (2.8–6.4) | 8.3 (6.3–10.9)
Education
Less than high school | 36.2 (33.4–39.1) | 26.5 (24.0–29.1) | 31.5 (29.5–33.5)
High school graduate | 31.3 (29.5–33.1) | 23.6 (22.1–25.3) | 27.4 (26.2–28.6)
Some college | 25.9 (24.1–27.8) | 21.4 (19.9–22.9) | 23.4 (22.2–24.7)
College graduate | 11.1 (9.8–12.5) | 9.7 (8.6–10.9) | 10.4 (9.5–11.3)
Age group (years)
18–25 | 28.4 (27.1–29.6) | 20.7 (19.7–21.8) | 24.6 (23.7–25.5)
26–44 | 31.6 (30.0–33.1) | 23.2 (21.9–24.5) | 27.3 (26.2–28.4)
45–64 | 23.7 (21.9–25.7) | 20.8 (19.2–22.4) | 22.2 (20.9–23.5)
≥65 | 9.9 (7.9–12.3) | 9.4 (7.7–11.4) | 9.6 (8.3–11.2)
Poverty status
At or above poverty level | 22.9 (21.9–23.8) | 17.3 (16.4–18.2) | 20.0 (19.3–20.8)
Below poverty level | 37.8 (35.1–40.6) | 28.9 (26.8–31.0) | 32.5 (30.8–34.3)
Unknown^c^ | 8.9 (5.2–14.8) | 6.1 (3.9–9.4) | 7.5 (5.0–11.1)
Region
Northeast | 23.2 (21.1–25.3) | 18.3 (16.6–20.0) | 20.6 (19.3–22.0)
Midwest | 26.5 (24.9–28.2) | 23.7 (22.1–25.4) | 25.1 (23.8–26.4)
South | 26.2 (24.6–27.9) | 19.8 (18.4–21.3) | 22.9 (21.7–24.0)
West | 22.2 (20.1–24.4) | 15.4 (13.7–17.1) | 18.7 (17.3–20.2)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval.

a Current smoking is defined as smoking in the 30 days preceding the survey and having used 100 cigarettes or more in lifetime. Respondents with unknown lifetime number of cigarettes consumed were excluded from the analysis.

b Low precision; no estimate reported.

c Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

Figure 13.4 Trends in prevalence (%) of current cigarette smoking among adults, 18 years of age and older, by gender; National Health Interview Survey (NHIS) 1965–2012; United States

Source: 1965–2012 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1965 to 2012 current smoking among adults, 18 years of age and older, generally decreased annually in men (from more than 50 percent in 1965 to more than 20 percent in 2012) and women (from nearly 35 percent in 1965 to less than 20 percent in 2012).

As noted earlier, the measurements of the prevalence of adult smoking for NSDUH are based on smoking at least 100 cigarettes in a lifetime (plus smoking in the last 30 days); the difference between this standard and the NSDUH standard for young adults (smoked all or part of a cigarette in the past 30 days) explains the differences for adults 18–25 years of age between Table 13.3 and Table 13.4.

Adults 18–25 and 26–44 years of age had the highest prevalence estimates for current smoking, 24.6% and 27.3%, respectively. The prevalence of smoking then declined with age. Current cigarette smoking and the level of education were inversely associated. In 2012, 10.4% of those with at least a college degree were current cigarette smokers, compared with 31.5% of those who had less than a high school education. Lastly, the prevalence of current smoking was higher among those living below the poverty line (32.5%) than among those living at or above the poverty line (20.0%).

### Daily Versus Intermittent Smoking

Research suggests that as many as one-fifth of current smokers do not smoke on a daily basis (Trinidad et al. 2009); moreover, the frequency of daily use varies considerably between youth, young adults, and adults. This section examines patterns of daily smoking among youth, young adult, and adult current smokers and also presents the prevalence of intermittent and daily smoking for adults. NSDUH defines daily cigarette smoking as smoking on all 30 days of the previous month. Intermittent smoking is defined as smoking in the past month, but not daily, among current smokers.

#### Adolescents and Young Adults

Table 13.5 presents the prevalence of daily smoking among 12- to 17-year-olds who had smoked cigarettes during the previous month. Overall, 22.0% of youth cigarette smokers were daily smokers. As a percentage, daily smoking among youth smokers was not significantly different between males and females; however, it was more common among Whites than Blacks or Hispanics. The prevalence of daily smoking increased with greater age. By region, the prevalence of daily smoking did not vary significantly by region.

Table 13.5 Prevalence of intermittent^a^ and daily^b^ cigarette smoking among young people who are past-month cigarette users^c^, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | 12–17 years of age | | 18–25 years of age
Characteristic
Characteristic | Intermittent^a^ % (95% CI) | Daily^b^ % (95% CI) | Intermittent^a^ % (95% CI) | Daily^b^ % (95% CI)
Overall | 78.0 (75.3–80.5) | 22.0 (19.5–24.7) | 54.9 (53.1–56.6) | 45.1 (43.4–46.9)
Gender
Male | 79.0 (75.2–82.4) | 21.0 (17.6–24.8) | 57.4 (55.2–59.5) | 42.6 (40.5–44.8)
Female | 76.9 (72.9–80.4) | 23.1 (19.6–27.1) | 51.5 (49.0–53.9) | 48.5 (46.1–51.0)
Race/ethnicity
White, non-Hispanic | 74.3 (71.1–77.3) | 25.7 (22.7–28.9) | 47.2 (45.1–49.2) | 52.8 (50.8–54.9)
Male | 76.1 (71.5–80.1) | 23.9 (19.9–28.5) | 48.9 (46.2–51.6) | 51.1 (48.4–53.8)
Female | 72.4 (67.3–77.0) | 27.6 (23.0–32.7) | 45.0 (42.1–47.9) | 55.0 (52.1–57.9)
Black or African American, non-Hispanic | 86.7 (77.3–92.6) | 13.3 (7.4–22.7) | 65.5 (61.3–69.5) | 34.5 (30.5–38.7)
Male | –^d^ | –^d^ | 66.8 (61.5–71.7) | 33.2 (28.3–38.5)
Female | –^d^ | –^d^ | 63.9 (56.5–70.6) | 36.1 (29.4–43.5)
Hispanic or Latino | 86.7 (79.2–91.8) | 13.3 (8.2–20.8) | 75.9 (72.0–79.5) | 24.1 (20.5–28.0)
Male | –^d^ | –^d^ | 80.9 (76.6–84.5) | 19.1 (15.5–23.4)
Female | 89.1 (79.6–94.4) | 10.9 (5.6–20.4) | 67.2 (60.6–73.1) | 32.8 (26.9–39.4)
Other^e^ | 84.3 (74.9–90.6) | 15.7 (9.4–25.1) | 59.9 (52.5–66.8) | 40.1 (33.2–47.5)
Male | –^d^ | –^d^ | 58.0 (49.3–66.2) | 42.0 (33.8–50.7)
Female | –^d^ | –^d^ | 62.7 (52.7–71.8) | 37.3 (28.2–47.3)
Age (in years)
12–13 | –^d^ | –^d^ | NA | NA
14–15 | 86.8 (82.6–90.0) | 13.2 (10.0–17.4) | NA | NA
16–17 | 74.1 (70.5–77.3) | 25.9 (22.7–29.5) | NA | NA
18–20 | NA | NA | 62.7 (60.0–65.4) | 37.3 (34.6–40.0)
21–23 | NA | NA | 52.5 (49.9–55.1) | 47.5 (44.9–50.1)
24–25 | NA | NA | 48.1 (45.1–51.1) | 51.9 (48.9–54.9)
Poverty status
At or above poverty level | 78.1 (74.9–81.0) | 21.9 (19.0–25.1) | 53.6 (51.7–55.5) | 46.4 (44.5–48.3)
Below poverty level | 77.7 (72.2–82.4) | 22.3 (17.6–27.8) | 55.5 (52.1–58.9) | 44.5 (41.1–47.9)
Unknown^f^ | NA | NA | 89.4 (84.3–93.0) | 10.6 (7.0–15.7)
Region
Northeast | 75.5 (68.3–81.6) | 24.5 (18.4–31.7) | 55.1 (51.1–59.0) | 44.9 (41.0–48.9)
Midwest | 76.3 (71.6–80.4) | 23.7 (19.6–28.4) | 47.2 (44.1–50.3) | 52.8 (49.7–55.9)
South | 77.5 (72.8–81.7) | 22.5 (18.3–27.2) | 54.9 (52.1–57.8) | 45.1 (42.2–47.9)
West | 83.3 (75.9–88.7) | 16.7 (11.3–24.1) | 63.3 (59.7–66.9) | 36.7 (33.1–40.3)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval; NA = not applicable.

a Intermittent smoking is defined as smoking in the past month but not daily, among current smokers.

b Daily smokers are defined as smoking daily among current smokers.

c Based on responses to the question “During the past 30 days, have you smoked part or all of a cigarette?” Respondents who chose “Yes” were classified as current smokers.

d Low precision; no estimate reported.

e Includes Asian, American Indian or Alaska Native, Native Hawaiian or Other Pacific Islander, and persons of 2 or more races.

f Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

For all variables on which comparisons can be made, the prevalence of daily smoking among past-month smokers was higher for young adults (18–25 years of age) than for youth (12–17 years of age) (Table 13.5). Overall, 45.1% of young adult smokers were daily smokers. Females had a higher rate than males, and as among youth, the highest rate by race/ethnicity was among Whites (52.8%). Daily smoking increased with age, with the rate rising from 37.3% for those 18–20 years of age to 51.9% for the 24–25 years of age group. Regionally, the highest rate was observed in the Midwest and the lowest in the West.

#### Adults

In 2012, an estimated 61.9% of adult current cigarette smokers were daily smokers; conversely, 38.1% had smoked only on some days during the previous month (Table 13.6). Daily smoking was higher for females (64.9%) than males (59.3%). By race/ethnicity, Whites had the highest rate of daily smoking (68.6%). Notably, lower rates of daily smoking were found among Asians, Blacks, and Hispanics. In general, daily smoking was inversely related to educational status. Current smokers living at or above the poverty line had a higher rate of daily smoking (62.6%) than those below the poverty line (60.4%). By region, the highest rates of daily smoking were observed in the Midwest (68.3%).

Table 13.6 Prevalence of intermittent^a^ and daily^b^ cigarette smoking among adults 18 years of age and older among past-month cigarette users^c^, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | Intermittent^a^ % (95% CI) | Daily^b^ % (95% CI)
Overall | 38.1 (36.7–39.6) | 61.9 (60.4–63.3)
Gender
Male | 40.7 (38.8–42.7) | 59.3 (57.3–61.2)
Female | 35.1 (33.2–37.1) | 64.9 (62.9–66.8)
Race/ethnicity
White, non-Hispanic | 31.4 (29.9–33.0) | 68.6 (67.0–70.1)
Black, non-Hispanic | 51.9 (47.5–56.3) | 48.1 (43.7–52.5)
Hispanic | 62.2 (57.6–66.6) | 37.8 (33.4–42.4)
American Indian/Alaska Native, non-Hispanic | –^d^ | –^d^
Asian, non-Hispanic | 47.2 (35.8–59.0) | 52.8 (41.0–64.2)
Education
Less than high school | 34.0 (31.1–37.1) | 66.0 (62.9–68.9)
High school graduate | 34.0 (31.8–36.3) | 66.0 (63.7–68.2)
Some college | 39.4 (36.8–42.0) | 60.6 (58.0–63.2)
College graduate | 52.4 (48.5–56.3) | 47.6 (43.7–51.5)
Age (in years)
18–25 | 54.9 (53.1–56.6) | 45.1 (43.4–46.9)
26–44 | 38.2 (36.1–40.4) | 61.8 (59.6–63.9)
45–64 | 30.5 (27.8–33.4) | 69.5 (66.6–72.2)
≥65 | 27.4 (21.4–34.3) | 72.6 (65.7–78.6)
Poverty status
At or above poverty level | 37.4 (35.8–39.1) | 62.6 (60.9–64.2)
Below poverty level | 39.6 (36.7–42.5) | 60.4 (57.5–63.3)
Unknown^e^ | 89.4 (84.3–93.0) | 10.6 (7.0–15.7)
Region
Northeast | 39.4 (36.4–42.4) | 60.6 (57.6–63.6)
Midwest | 31.7 (29.4–34.0) | 68.3 (66.0–70.6)
South | 39.0 (36.6–41.5) | 61.0 (58.5–63.4)
West | 43.1 (39.6–46.7) | 56.9 (53.3–60.4)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval.

a Intermittent smoking is defined as smoking in the past month but not daily, among current smokers.

b Daily smokers are defined as smoking daily among current smokers.

c Based on responses to the question “During the past 30 days, have you smoked part or all of a cigarette?” Respondents who chose “Yes” were classified as current smokers.

d Low precision; no estimate reported.

e Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

In contrast to the data reported above showing that female smokers had a higher prevalence of daily smoking than males when female and male current smokers were used for the corresponding denominators, the prevalence of daily smoking in 2012 was higher among males (15.8%) than females (13.7%) (Table 13.7). This is because adult males had a higher prevalence of current smoking than adult females (26.7% vs. 21.1%).

Table 13.7 Prevalence of intermittent^a^ and daily^b^ cigarette smoking among adults 18 years of age and older, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | Intermittent^a^ % (95% CI) | Daily^b^ % (95% CI)
Overall | 9.1 (8.7–9.5) | 14.7 (14.1–15.3)
Gender
Male | 10.9 (10.3–11.5) | 15.8 (15.0–16.6)
Female | 7.4 (6.9–7.9) | 13.7 (13.0–14.4)
Race/ethnicity
White, non-Hispanic | 7.9 (7.5–8.4) | 17.2 (16.5–18.0)
Black, non-Hispanic | 13.2 (11.8–14.8) | 12.2 (10.8–13.8)
Hispanic | 11.6 (10.4–12.9) | 7.0 (6.1–8.2)
American Indian/Alaska Native, non-Hispanic | 19.8 (14.0–27.4) | 22.3 (16.3–29.8)
Asian, non-Hispanic | 4.8 (3.7–6.2) | 5.4 (3.7–7.8)
Education
Less than high school | 11.5 (10.3–12.8) | 22.3 (20.7–23.9)
High school graduate | 10.0 (9.3–10.8) | 19.4 (18.4–20.6)
Some college | 10.0 (9.3–10.8) | 15.4 (14.4–16.5)
College graduate | 6.0 (5.4–6.7) | 5.5 (4.8–6.2)
Age (in years)
18–25 | 17.5 (16.7–18.2) | 14.4 (13.7–15.1)
26–44 | 11.0 (10.3–11.8) | 17.9 (16.9–18.8)
45–64 | 6.9 (6.2–7.7) | 15.7 (14.7–16.8)
≥65 | 2.7 (2.1–3.6) | 7.3 (6.1–8.7)
Poverty status
At or above poverty level | 8.1 (7.6–8.5) | 13.5 (12.9–14.1)
Below poverty level | 14.1 (13.0–15.4) | 21.6 (20.1–23.2)
Unknown^c^ | 19.7 (14.6–26.1) | 2.3 (1.2–4.4)
Region
Northeast | 8.8 (8.0–9.7) | 13.6 (12.5–14.8)
Midwest | 8.4 (7.7–9.1) | 18.1 (17.0–19.3)
South | 9.7 (9.0–10.4) | 15.1 (14.2–16.1)
West | 8.9 (8.0–9.9) | 11.7 (10.6–13.0)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval.

a Intermittent smoking is defined as smoking in the past month but not daily.

b Daily smokers are defined as smoking daily.

c Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

American Indians/Alaska Natives and Whites had the highest prevalence of daily smoking. For intermittent smoking, Blacks had about the same prevalence (13.2%) as they did for daily smoking (12.2%). In contrast, among Hispanics there were more intermittent smokers (11.6%) than daily smokers (7.0%), but for Whites and American Indians/Alaska Natives the opposite was true, with the rates for Whites being 17.2% for daily and just 7.9% for intermittent. Education was inversely related to daily smoking, but by age there was no clear trend under 65 years of age (those 65 years of age or older had the lowest rate of daily smoking by far, 7.3%). The 18–25 years of age group was the only age category in which the estimate for intermittent smoking was higher than the estimate for daily smoking, a pattern that is consistent with the evolving smoking behavior of young adults. In 2012, intermittent smoking decreased steadily with age. Regarding poverty status, the prevalence of daily smoking was much higher among those below the poverty level (21.6%) than among those at or above this level (13.5%). Similarly, the prevalence of intermittent smoking was higher for those below the poverty level than among those at or above this standard. Last, by region the Midwest and South had the highest prevalence of daily smoking.

### Cessation

#### Attempts to Quit Smoking in the Past Year

Attempts to quit cigarette smoking (“quit attempts”) are considered an important intermediate step to increasing rates of cessation and, thereby, reducing the overall prevalence of smoking. In the 2012 NHIS, adult participants who were current daily smokers were asked whether they had stopped smoking for more than 1 day in the past 12 months because they were trying to quit. As reported in Table 13.8, an estimated 42.7% of daily smokers in 2012 had attempted to quit smoking in the past year. The prevalence of quit attempts did not differ significantly by gender. Black (49.3%) and Hispanic (51.8%) daily smokers had a higher prevalence of quit attempts than did their White counterparts (40.9%). In general, education was associated with attempting to quit, with the college-educated group having the highest percentage (49.0%). There was an inverse association with age, as young adults had the highest prevalence of attempting to quit (48.5%) and those 65 years of age or older had the lowest rate (34.6%). Last, the prevalence of attempting to quit did not differ significantly by poverty status.

Table 13.8 Percentage of current adult daily cigarette smokers 18 years of age and older who attempted to quit smoking during the past year or had an interest in quitting smoking, by selected characteristics; National Health Interview Survey (NHIS) 2010 and 2012; United States

Characteristic | Attempted to quit smoking (2012) % (95% CI) | Had an interest in quitting smoking (2010) % (95% CI)
Total | 42.7 (40.9–44.5) | 68.9 (67.1–70.8)
Gender
Male | 43.1 (40.6–45.6) | 67.8 (65.2–70.4)
Female | 42.2 (39.7–44.7) | 70.1 (67.6–72.7)
Race/ethnicity
White, non-Hispanic | 40.9 (38.7–43.1) | 69.4 (67.1–71.6)
Black, non-Hispanic | 49.3 (45.0–53.6) | 74.1 (69.6–78.5)
Hispanic | 51.8 (45.7–57.9) | 58.4 (52.8–64.0)
American Indian/Alaska Native, non-Hispanic | —^a^ | 52.1 (31.1–73.2)
Asian, non-Hispanic | 39.4 (29.2–49.6) | 63.3 (53.5–73.1)
Education^b^
≤8 years | 35.5 (27.9–43.1) | 64.5 (56.7–72.4)
9–11 (including 12 years, no diploma) | 39.0 (34.3–43.6) | 71.1 (66.9–75.3)
High school diploma | 40.0 (36.9–43.1) | 66.5 (63.4–69.6)
Some college | 44.3 (41.3–47.2) | 72.1 (69.0–75.1)
≥College | 49.0 (43.3–54.6) | 72.5 (67.4–77.6)
Age group (years)
18–24 | 48.5 (41.9–55.1) | 65.8 (59.8–71.8)
25–44 | 46.8 (44.0–49.6) | 74.3 (71.7–76.9)
45–64 | 38.8 (36.2–41.4) | 68.3 (65.6–71.0)
≥65 | 34.6 (29.6–39.7) | 52.7 (46.7–58.6)
Poverty status
At or above poverty level | 43.8 (41.6–46.0) | 69.9 (67.7–72.1)
Below poverty level | 40.4 (36.9–43.9) | 66.6 (62.8–70.4)
Unknown^c^ | 39.1 (32.7–45.5) | 66.1 (60.0–72.2)
Region
Northeast | 44.2 (39.6–48.8) | 70.6 (65.2–76.0)
North Central | 42.6 (38.9–46.3) | 69.9 (66.2–73.6)
South | 42.1 (39.4–44.8) | 68.6 (65.7–71.5)
West | 42.9 (39.2–46.7) | 66.8 (63.3–70.2)

Source: 2010 and 2012 NHIS: National Center for Health Statistics, public use data tapes.

Note: CI = confidence interval.

a Low precision; no estimate reported.

b Education is reported for adults ≥25 years of age only.

c Respondents 18–22 years of age currently living in a college dormitory were included in the Unknown category.

#### Interest in Quitting Smoking

According to the 2010 NHIS, 68.9% of current adult daily smokers in that year were interested in quitting smoking (Table 13.8). As was the case among smokers who attempted to quit, estimates for interest in quitting did not differ significantly by gender or poverty status. In contrast, estimates differed significantly by race/ethnicity, with Whites and Blacks having the highest absolute estimates. In general, those with higher levels of education had more interest in quitting, although those with at least 9 years of education but no diploma had an estimate of 71.1%, quite similar to the estimates for those with some college education (72.1%) and those with at least a college degree (72.5%). Beginning with the 25–44 years of age group, the estimates for interest in quitting decreased with each age group.

#### Quit Ratio

In 2012, the overall quit ratio (i.e., the percentage of ever smokers who had quit smoking) among U.S. adults was 55.1% (Table 13.9), which means that in that year there were more former smokers than there were current smokers in the United States. The quit ratio was almost the same for men and women. By race/ethnicity, Whites (57.1%) and Asians (51.8%) had the highest quit ratios, and Blacks (44.1%) and American Indians/Alaska Natives (48.2%) had the lowest. Beginning with the group that had at least 9 years of education but no high school diploma, the quit ratio increased as level of education rose. Both greater age and not living in poverty were positively correlated with the quit ratio.

Table 13.9 Percentage of ever cigarette smokers 18 years of age and older who have quit smoking (i.e., the quit ratio), by selected characteristics; National Health Interview Survey (NHIS) 2012; United States

Characteristic | Quit ratio % (95% CI)
Overall | 55.1 (54.0–56.2)
Gender
Male | 55.3 (53.8–56.8)
Female | 54.8 (53.2–56.3)
Race/ethnicity
White, non-Hispanic | 57.1 (55.8–58.4)
Black, non-Hispanic | 44.1 (41.0–47.3)
Hispanic | 53.6 (50.4–56.8)
American Indian/Alaska Native, non-Hispanic | 48.2 (35.7–60.6)
Asian, non-Hispanic | 51.8 (46.2–57.4)
Education^a^
≤8 years | 57.6 (52.9–62.3)
9–11 (including 12 years, no diploma) | 43.5 (40.2–46.8)
High school diploma | 50.9 (48.8–53.0)
Some college | 57.1 (55.0–59.1)
≥College | 73.9 (71.9–75.9)
Age group (years)
18–24 | 26.5 (22.4–30.5)
25–44 | 40.7 (38.8–42.6)
45–64 | 56.9 (55.0–58.7)
≥65 | 82.1 (80.5–83.7)
Poverty status
At or above poverty level | 57.5 (56.2–58.8)
Below poverty level | 34.5 (31.9–37.0)
Unknown^b^ | 64.7 (61.7–67.7)
Region
Northeast | 59.0 (55.9–62.0)
North Central | 51.2 (49.1–53.4)
South | 52.3 (50.3–54.3)
West | 61.1 (59.1–63.1)

Source: 2012 NHIS: National Center for Health Statistics, public use data tapes.

Note: CI = confidence interval.

a Education is reported for adults ≥25 years of age only.

b Respondents 18–22 years of age currently living in a college dormitory were included in the Unknown category.

#### Trends Over Time in the Quit Ratio

The percentage of ever smokers who had quit increased sharply in both genders between 1965 and the early 1990s, but for males this rate has changed little since then (Figure 13.5). Furthermore, although for a long time males had a substantially higher quit ratio than females, females did not experience the same plateau as males, with the ratio for females substantially higher in 2011 than in the early 1990s. By 2005, the difference between the genders was trivial. Regardless, although the quit ratio is a useful indicator, analyses of changes over time in this ratio for a group, or for the entire U.S. population, needs to be interpreted in light of changes in the age distribution of the population of interest. As shown in Figure 13.7, the percentage of ever smokers who quit smoking increased over time for all age groups except for young adults (18–24 years of age) whose quit ratio has changed little over 45 years. The greatest gains were observed among those 65 years of age and older; this age group continued its gains even during the 1990s and beyond when the quit ratio leveled out for all other age groups. Thus, to more fully appreciate the changes seen over time in the quit ratio by gender or another classification, one would have to look at changes within specific age groups and, moreover, changes in the relative size of these different age groups.

Figure 13.5 Percentage of ever cigarette smokers 18 years of age and older who had quit smoking (i.e., the quit ratio), by gender; National Health Interview Survey (NHIS) 1965–2012; United States

Source: 1965–2012 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1965 to 2012 the percentage of ever smokers, 18 years of age and older, who had quit smoking increased dramatically in males and females through the early 1990s and then slightly through 2012. Among males, 27 percent of ever smokers quit smoking in 1965 compared with 55 percent in 2012. Among females, 19 percent of ever smokers quit smoking in 1965 compared with 54 percent in 2012.

Figure 13.7 Percentage of ever cigarette smokers 18 years of age and older who had quit smoking (i.e., the quit ratio), by race/ethnicity; National Health Interview Survey (NHIS) 1965–2012; United States

Source: 1965–2012 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1965 to 2012 the percentage of ever smokers, 18 years of age and older, who had quit smoking increased dramatically by race/ethnicity through the early 1990s and then moderately through 2012. Among White, non-Hispanics, 25 percent of ever smokers quit smoking in 1965 compared with 57 percent in 2012. Among Black, non-Hispanics, 15 percent of ever smokers quit smoking in 1965 compared with 44 percent in 2012. Among Hispanics, 33 percent of ever smokers quit smoking in 1978 compared with 53 percent in 2012.

In terms of race/ethnicity, as shown in Figure 13.6, for decades Whites had a higher quit ratio than Hispanics and Blacks, but by 2010 the gap between Whites and Hispanics was negligible, underscoring the fact that the quit ratio among Hispanics had increased considerably over time. The quit ratio for Black smokers, in contrast, did not move closer to Whites over time. Still, as noted above, one would have to examine the changes in age distribution over the years within a racial/ethnic group to more fully understand the trends in the quit ratio by that classification.

Figure 13.6 Percentage of ever cigarette smokers 18 years of age and older who had quit smoking (i.e., the quit ratio), by age group; National Health Interview Survey (NHIS) 1965–2012; United States

Source: 1965–2012 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1965 to 2012 the percentage of ever smokers, 18 years of age and older, who had quit smoking approximately doubled in the three youngest age groups: 18–24 years of age (from 13 percent in 1965 to 26 in 2012), 25–44 years of age (from 21 percent in 1965 to 40 percent in 2012), 45–64 years of age (from 27 percent in 1965 to 56 percent in 2012). Among those 65 years of age and older, 45 percent quit smoking in 1965 compared with 82 percent in 2012.

### Trends Over Time in Smoking

#### Adolescents

National YRBS data (Figure 13.8) indicate that the decline in the prevalence of current cigarette smoking among students was nonlinear during the past two decades, highlighting the decline in the prevalence of current smoking among youth that began after the Master Settlement Agreement (MSA) in 1998. Figure 13.8 illustrates that the prevalence of cigarette smoking increased among high school students from 1991–1997, hit a peak in 1997 before the MSA in 1998, and then began a steep decline (Nelson et al. 2008; Centers for Disease Control and Prevention [CDC] 2010) from 1997–2003 and then a more gradual decline from 2003–2011. In 1991, about one-quarter (27.6% of males, 27.3% of females) of high school students were current smokers (Figure 13.8A). By 1997, the prevalence of current smoking had increased to more than one-third (37.7% males, 34.7% females) of high school students. Nonetheless, current cigarette smoking among students was at its lowest point in 2011 with less than one in five high school students smoking (19.9% males, 16.1% females). These trends in current cigarette smoking were reasonably consistent across racial/ethnic subgroups (Figure 13.8B).

Figure 13.8 Trends over time in the prevalence of current cigarette smoking among high school students, by gender and race/ethnicity; National Youth Risk Behavior Survey (YRBS) 1991–2011; United States

Source: 1991–2011 National YRBS, Centers for Disease Control and Prevention.

Note: Prevalence based on responses to the question “During the past 30 days, on how many days did you smoke cigarettes?” Respondents who reported that they had smoked cigarettes on at least 1 day during the 30 days before the survey were classified as current smokers.

Part A Line graph shows that from 1991 to 2011 the percentage of frequent cigarette smoking among U.S. high school students of both genders rose moderately through the late 1990s, then decreased dramatically through 2003, and continued to decrease but at a much slower rate through 2011. Among males, 27 percent of high school students smoked frequently in 1991 compared with 20 percent in 2011. Among females, 27 percent of high school students smoked frequently in 1991 compared with 16 percent in 2011. Part B Line graph shows that from 1991 to 2011 the percentage of frequent cigarette smoking among U.S. high school students of various races/ethnicities peaked in the mid- to late 1990s and then generally decreased, more so in White and Black, non-Hispanics than in Hispanics, through 2011. Among White, non-Hispanics, 31 percent of high school students smoked frequently in 1991 compared with 20 percent in 2011. Among Black, non-Hispanics, 12 percent of high school students smoked frequently in 1991 compared with 10 percent in 2011. Among Hispanics, 25 percent of high school students smoked frequently in 1991 compared with 17 percent in 2011.

#### Adults

In the years before the 1964 Surgeon General's report, the prevalence of cigarette smoking was already declining among men but was still rising among women (Figure 13.9) (Warner and Murt 1982). Figures 13.4, 13.10, and 13.11 display long-term trends in current cigarette smoking using NHIS data from 1965–2012. Among all adults (18 years of age or older), the prevalence of current cigarette smoking declined steadily over time from 1965 (42.4%) to 2012 (18.1%). Most of this decline reflected reductions in current smoking among males (Figure 13.4). In 1965, just over one-half (51.9%) of males were current cigarette smokers—in 2011, less than one-fifth (19.0%) were. The decline for females was steady but less dramatic: in 1965, about one-third (33.9%) of females were current cigarette smokers—in 2011, less than one-fifth (17.3%) were. Although trends in current smoking among Blacks, Whites, and Hispanics varied over time (Figure 13.10), current smoking declined among all three groups from 1965–2011. Similarly, the prevalence of current cigarette smoking from 1965–2011 declined for all four age groups (Figure 13.11). From 2005–2011, the most marked decline was seen in those 18–24 years of age (from 24.4 to 18.9%).

Figure 13.9 Prevalence of current cigarette smokers, by gender, calendar year, and birth cohort

Source: Holford et al. in press. American Journal of Preventive Medicine. February 2014; online only.

Part A Line graph shows that the prevalence of current cigarette smoking among males (a) was generally higher among older birth cohorts than younger birth cohorts and (b) decreased as respective birth cohorts aged. In addition, older birth cohorts tended to achieve higher prevalence rates for lengthier periods of time than younger birth cohorts. Each of the 13 oldest birth cohorts (1890, 1895, 1900, 1905, 1910, 1915, 1920, 1925, 1930, 1935, 1940, 1945, and 1950) achieved a prevalence rate greater than 50 percent at one time or the other. None of the younger male birth cohorts (1965, 1970, 1975, 1980, 1985, 1990, 1995, and 2000) reached a prevalence rate greater than 40 percent at any one time. Part B Line graph shows that except for the earliest birth cohorts the prevalence of current cigarette smoking among females (a) was generally higher among older birth cohorts than younger birth cohorts and (b) decreased as respective birth cohorts aged. The highest prevalence rates were observed among birth cohorts from 1915 to 1945. Each of these birth cohorts (1915, 1920, 1925, 1930, 1935, 1940, and 1945) achieved a prevalence rate greater than 40 percent at one time or the other. Prevalence rates between 30 and 39 percent were observed among birth cohorts from 1950, 1955, 1960, and 1965. Prevalence rates of the youngest birth cohorts (1970, 1975, 1980, 1985, and 1990) never exceeded 27 percent. The lowest prevalence rates were observed among the oldest birth cohorts (1890, 1895, and 1900), topping out at 19 percent.

Figure 13.10 Trends in prevalence (%) of current cigarette smoking among adults 18 years of age and older, by race/ethnicity; National Health Interview Survey (NHIS) 1965–2012; United States

Source: 1965–2012 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1965 to 2012 the prevalence of current cigarette smoking among adults generally decreased by race/ethnicity: White, non-Hispanics (from 42 percent in 1965 to 20 percent in 2012); Black, non-Hispanics (from 46 percent in 1965 to 18 percent in 2012); and Hispanics (from 31 percent in 1978 to 12 percent in 2012).

Figure 13.11 Trends in prevalence (%) of current cigarette smoking among adults, by age group; National Health Interview Survey (NHIS) 1965–2012; United States

Source: 1965–2012 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1965 to 2012 the prevalence of current cigarette smoking among adults generally decreased among the three oldest age groups: 25–44 years of age (from 51 percent in 1965 to 21 percent in 2012), 45–64 years of age (from 41 percent in 1965 to 19 percent in 2012), and 65 years of age and older (from 18 percent in 1965 to 9 percent in 2012). Among those in the youngest age group (18–24 years of age), smoking generally decreased from 1965 (45 percent) to 2012 (17 percent), except for a slight increase from the mid-1990s and early 2000s.

Using data from NHIS for 1991–2012, Figures 13.12, 13.13, and 13.14 show trends in the prevalence of daily cigarette smoking by gender, race/ethnicity, and age group, respectively. As noted earlier in this chapter, most adult current smokers smoke daily. Figure 13.12 shows that the prevalence of daily smoking among adults 18 years of age or older declined slowly but steadily over time for both genders, but by 2007, this trend flattened out. Overall, the prevalence of daily smoking declined by 7.8% for males and 6.8% for females from 1991–2011 (Figure 13.12). The trends over time by racial/ethnic group from 1991–2011 were more diverse (Figure 13.13); among Whites, the prevalence declined by 6.3%, while among Blacks the rate declined 8.5%. Among Hispanics, however, the prevalence dropped over one-half, going from 14.4% in 1991 to 7% in 2011, or a 7.4% decline. Among all three racial/ethnic groups, the declines slowed and/or stalled between 2007–2011. Figure 13.14 shows all four age groups had a lower prevalence at the end of the period than at the beginning, with the greatest decline noted among smokers 25–44 years of age whose prevalence of daily smoking declined by 9.5%. The youngest group (18–24 years of age) differed from the other three age groups by experiencing a notable increase in daily smoking during part of the period; its rate rose from 18.2% in 1991 to 21.4% in 2002 before declining sharply to 13.2% in 2011. The other three age groups have experienced a slowing of their declines in the prevalence of daily smoking since 2007, no longer increasing for smokers 45–64 years of age.

Figure 13.12 Trends in prevalence (%) of daily cigarette smokinga among adults 18 years of age and older, by gender; National Health Interview Survey (NHIS) 1991–2012b; United States

^a^ Current daily smokers in NHIS included adult respondents who reported smoking ≥100 cigarettes in their lifetime and specified currently smoking “every day.”

^b^ Data for daily smoking were not available before 1991 or in 1996.

Source: 1991–2012 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1991 to 2012 the prevalence of daily cigarette smoking among U.S. adults of both genders generally decreased moderately. Among males, 24 percent of adults smoked daily in 1991 compared with 16 percent in 2012. Among females, 20 percent of adults smoked frequently in 1991 compared with 12 percent in 2011.

Figure 13.13 Trends in prevalence (%) of daily cigarette smokinga among adults 18 years of age and older, by race/ethnicityb; National Health Interview Survey (NHIS) 1991–2012c; United States

^a^ Current daily smokers in NHIS included adult respondents who reported smoking ≥100 cigarettes in their lifetime and specified currently smoking “every day.”

^b^ In 1999, NHIS began reporting race according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity. Before 1999, data were reported according to the 1977 Standards and are not strictly comparable to later years. In 2000, NHIS began reporting Hispanic ethnicity (which includes persons of Hispanic, Latino, or Spanish descent).

^c^ Data for daily smoking were not available before 1991 or in 1996.

Source: 1991–2012 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1991 to 2012 the prevalence of adults, 18 years of age and older, who smoked daily decreased moderately by race/ethnicity. Among White, non-Hispanics, 23 percent of adults smoked daily in 1991 compared with 16 percent in 2012. Among Black, non-Hispanics, 23 percent of adults smoked daily in 1991 compared with 13 percent in 2012. Among Hispanics, 14 percent of adults smoked daily in 1991 compared with 7 percent in 2012.

Figure 13.14 Trends in prevalence (%) of daily cigarette smokinga among adults, by age group; National Health Interview Survey (NHIS) 1991–2012b; United States

^a^ Current daily smokers included adult respondents who reported smoking ≥100 cigarettes in their lifetime and specified currently smoking “every day.”

^b^ Data for daily smoking were not available before 1991 or in 1996.

Source: 1991–2012 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1991 to 2012 the prevalence of daily cigarette smoking among adults generally decreased among the three oldest age groups: 25–44 years of age (from 26 percent in 1991 to 16 percent in 2012), 45–64 years of age (from 24 percent in 1991 to 16 percent in 2012), and 65 years of age and older (from 12 percent in 1991 to 7 percent in 2012). Among those in the youngest age group (18–24 years of age), daily smoking generally decreased from 1965 (18 percent) to 2012 (12 percent), except for a slight upward trend from the mid-1990s to early 2000s.

### Smoking History by Birth Cohorts

Previous Surgeon General's reports have presented cross-sectional survey data when discussing historical trends in cigarette smoking (USDHHS 1989, 1994, 1998, 2000, 2012), but the present report will examine historical trends by using a different approach, one that is based on pooling and modeling the existing cross-sectional NHIS data. Specific details about the methodology used to generate these curves can be examined elsewhere (Anderson et al. 2012; Holford et al. in press).

Figure 13.9 provides estimates of the prevalence of current smoking by birth cohort and year for males (A) and females (B). Figures 13.15A (males) and 13.15B (females) show probabilities of smoking initiation by birth cohort and age, and Figures 13.16A (males) and 13.16B (females) provide estimates of the mean number of cigarettes smoked per day by birth cohort and year. Finally, Figures 13.17A (males) and 13.17B (females) present annual probabilities of cigarette smoking cessation by age and birth cohort.

Figure 13.15 Annual probabilities of initiating cigarette smoking, by gender, birth cohort, and age

Source: Holford et al. in press. American Journal of Preventive Medicine. February 2014; online only.

Part A Line graph shows that among decades-based birth cohorts from 1890 to 1980, the annual probabilities of cigarette smoking initiation among males increased sharply during the teenage years and then dropped steadily with age. Overall, cigarette smoking initiation was greatest between 15 and 18 years of age. Part B Line graph shows that among decades-based birth cohorts from 1890 to 1980, the annual probabilities of cigarette smoking initiation among females were greatest during the teenage years (approximately 15–18 years of age) and then dropped steadily with age. Overall, the increase in initiation was most pronounced among females in the seven youngest birth cohorts: 1920, 1930, 1940, 1950, 1960, 1970, and 1980. The increase in initiation was much more modest in the three oldest birth cohorts: 1890, 1900, and 1910.

Figure 13.16 Mean number of cigarettes smoked per day, by gender, year, and birth cohort

Source: Holford et al. in press. American Journal of Preventive Medicine. February 2014; online only.

Part A Line graph shows that the average number of cigarettes smoked per day by males (a) was higher among older birth cohorts than younger birth cohorts and (b) decreased as respective birth cohorts aged. At the greatest point of consumption, males in the 14 oldest birth cohorts (1890, 1895, 1900, 1905, 1910, 1915, 1920, 1925, 1930, 1935, 1940, 1945, 1950, and 1955) generally smoked on average 20–25 cigarettes per day. The greatest daily cigarette consumption by males in the next six birth cohorts (1960, 1965, 1970, 1975, 1980, and 1985) ranged from 10 to 18 cigarettes per day. The greatest daily cigarette consumption by males was lowest (8 or 9 cigarettes per day) among those in three youngest birth cohorts (1990, 1995, and 2000). Part B Line graph shows that the average number of cigarettes smoked per day by females (a) was higher among older birth cohorts than younger birth cohorts and (b) decreased as respective birth cohorts aged. At the greatest point of consumption, females in the 16 oldest birth cohorts (1890, 1895, 1900, 1905, 1910, 1915, 1920, 1925, 1930, 1935, 1940, 1945, 1950, 1955, 1960, and 1965) generally smoked on average 15–20 cigarettes per day. The greatest daily cigarette consumption by females in the next three birth cohorts (1970, 1975, and 1980) ranged from 10 to 13 cigarettes per day. The greatest daily cigarette consumption by females was lowest (8 or 9 cigarettes per day) among those in two youngest birth cohorts (1985 and 1990).

Figure 13.17 Annual probabilities of cigarette smoking cessation, by gender, age, and birth cohort

Source: Holford et al. in press. American Journal of Preventive Medicine. February 2014; online only.

Part A Line graph shows that among decades-based birth cohorts from 1890 to 1980, the annual probabilities of cigarette smoking cessation among males increased with age. The probabilities of cigarette smoking cessation were most pronounced later in life among the two oldest cohorts (1890 and 1900). The probabilities of cigarette smoking cessation trended steadily upward with age among the eight youngest cohorts (1910, 1920, 1930, 1940, 1950, 1960, 1970, and 1980). Overall, the probabilities of cigarette smoking cessation were higher earlier in life among younger birth cohorts compared with older birth cohorts. Part B Line graph shows that among decades-based birth cohorts from 1890 to 1980, the annual probabilities of cigarette smoking cessation among females increased with age. The increased probability of cigarette smoking cessation was most pronounced later in life among the oldest cohort (1890). The probabilities of cigarette smoking cessation trended steadily upward with age among the nine youngest cohorts (1900, 1910, 1920, 1930, 1940, 1950, 1960, 1970, and 1980). Overall, the probabilities of cigarette smoking cessation were higher earlier in life among younger birth cohorts compared with older birth cohorts.

The birth cohort curves for males and females allow for a much more detailed presentation of the history of cigarette smoking since the early twentieth century than was possible in early Surgeon General's reports. Past discussions of this history have focused primarily on the decline in the prevalence of adult current smoking since 1965 (Figure 13.4), with some estimates presented of higher smoking prevalence during the 1940s and 1950s (USDHHS 1989, 1994, 1998, 2000, 2012). As shown in Figure 13.9A, for males, each birth cohort curve rises sharply, reaches a peak, and then declines more slowly over time—indicating that developmental patterns of cigarette smoking among males have been relatively stable across generations. The rise in each curve for males that represents the initiation of smoking is illustrated in more detail in Figure 13.15A. For all birth cohorts, earliest smoking initiation began at about 10 years of age, with the probability of starting to smoke rising before peaking at about 17 years of age and then declining to almost nothing by about 30 years of age. This pattern for males was more prominent in the most recent birth cohorts.

Males who served in World War II or entered adolescence during the war years had the highest rates of smoking initiation (Figure 13.15A), with a peak in late adolescence of about 14–16% starting to smoke annually. As a result, among males born between 1915 and 1925, the curves show that over three-fourths of these men were current smokers by 30 years of age (Figure 13.9A). Among men born after 1925, the peak prevalence of smoking began to fall, slowly at first, but more rapidly up through males born around 1970. For males born from 1970 to 1994, the analyses indicate that the peak prevalence of current smoking in young adulthood has stopped declining and remains at about 30% (Holford et al. in press).

Among females, current smoking curves are distinctly different from those of males (Figure 13.9B). For females, the highest peak prevalence of current smoking was reached by those born between 1935–1939. Although the rate of smoking initiation (Figure 13.15B) and the rise in the current prevalence of smoking among females born from about 1930 to 1960 was more similar to those among males born between 1915–1925 than to those born in 1930–1960, the peak prevalence of current smoking reached by females, at about 45–50%, was lower than it was for males. But similar to the case with males, the curves of current smoking declined from these peak years down to the birth cohorts for 1980 and then for some time after, but they have stopped declining in recent birth cohorts (Holford et al. in press).

The curves describing the estimated probability of smoking initiation by age across the birth cohorts for males and females provide a more detailed picture of these patterns of initiation (Figures 13.15A and 13.15B). As noted in this chapter, among males across birth cohorts, the curve rises sharply, reaches a peak in late adolescence, and then declines, with little initiation beyond 30–35 years of age. By comparison, for females, initiation curves rise more slowly with age and extend into later ages, particularly among females born in 1980 and later. As shown in Figure 13.15B, among females, the peak annual initiation rates were lower than among males, particularly in comparisons of birth cohorts before 1920. In birth cohorts from 1920–1950, initiation rates among females became much higher and closer to those seen among males, but it was not until the 1960 birth cohorts that the actual rates became similar by gender (at about 6–8% per year in late adolescence), largely due to the sharp decline in peak initiation rates among men. Since the 1960s, initiation rates among males and females have been more similar (Holford et al. in press).

The decline in current smoking by calendar year in each birth cohort curve (Figure 13.9A for males and B for females) represents the impact of smoking cessation as a particular birth cohort ages and reflects the higher mortality of smokers. This later part of these curves shows larger differences across birth cohorts than the inclines that describe smoking initiation. In more recent birth cohorts, the decline in current smoking has been steeper and less protracted than in earlier birth cohorts, suggesting that smoking cessation now occurs at an increased frequency earlier in the life course. This interpretation is reinforced by data presented in Figure 13.17A for males and Figure 13.17B for females. At all ages, the probability of smoking cessation in the most recent birth cohorts exceeds that of earlier birth cohorts.

Larger differences across birth cohorts can also be observed with regard to daily consumption of cigarettes, illustrated in Figure 13.16A (males) and Figure 13.16B (females). In more recent birth cohorts, consumption has flattened greatly across the developmental life course, compared with earlier birth cohorts. The mean number of cigarettes smoked reached its highest level at about 25 cigarettes per day for males and about 20 cigarettes per day for females from 1970–1990. Since then, total consumption has fallen to its lowest levels and today remains at less than 10 cigarettes per day (Holford et al. in press).

## Other Tobacco Products

Although cigarettes remain the most prevalent form of tobacco use in the United States, the use of other tobacco products, such as cigars and smokeless tobacco, is still common. Data from the U.S. Department of Agriculture and trade data reported by industry indicate that although cigarette consumption has declined substantially, both the consumption and sale of moist snuff and cigars have risen (Maxwell 2012a,b,c). Moreover, some tobacco users consume more than one product, while others switch from one product to another (prompted by perceived harm reduction, differential prices, and/or smokefree air policies).

### Patterns of Smokeless Tobacco Use

Historically, the use of smokeless tobacco in the United States has been highest among White males (Bhattacharyya 2012). In the United States, smokeless tobacco is usually consumed in one of two forms: chewing tobacco, which is made up of long strands of tobacco; and snuff tobacco, a fine-grain tobacco that comes in either a moist blend or a dry or nasal form. Moist snuff is the most popular form of snuff and, indeed, is the most popular smokeless tobacco product. The amount of nicotine and nitrosamine varies widely in chewing tobacco and moist snuff, as it does between the different brands within each type (Richter and Spierto 2003; McNeill et al. 2006; Stepanov et al. 2006).

#### Current Prevalence Among Youth and Young Adults

Per NSDUH, the overall prevalence in 2012 of current use of smokeless tobacco was 2.1% for youth 12–17 years of age (Table 13.10). Current use was substantially more common among males (3.7%) than females (0.4%). In addition, the prevalence of current use of smokeless tobacco was significantly higher among White youth than Black, Hispanic, or “Other” youth; when gender and race/ethnicity are considered, the highest prevalence was among White males (5.8%). The percentage of youth who were current users of smokeless tobacco increased with age; no differences were observed by poverty status.

Table 13.10 Prevalence of current smokeless tobacco use^a^ among young people, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | 12–17 years of age % (95% CI) | 18–25 years of age % (95% CI)
Overall | 2.1 (1.8–2.3) | 5.5 (5.1–5.9)
Gender
Male | 3.7 (3.3–4.2) | 10.5 (9.8–11.3)
Female | 0.4 (0.3–0.5) | 0.5 (0.4–0.7)
Race/ethnicity
White, non-Hispanic | 3.2 (2.9–3.6) | 8.6 (8.0–9.2)
Male | 5.8 (5.1–6.6) | 16.2 (15.1–17.4)
Female | 0.5 (0.4–0.8) | 0.8 (0.6–1.1)
Black or African American, non-Hispanic | 0.4 (0.2–0.8) | 0.4 (0.2–0.8)
Male | 0.7 (0.4–1.4) | 0.9 (0.4–1.6)
Female | 0.1 (0.0–0.5) | 0.1 (0.0–0.5)
Hispanic or Latino | 0.5 (0.3–0.9) | 1.7 (1.3–2.3)
Male | 0.9 (0.6–1.6) | 3.1 (2.2–4.3)
Female | 0.1 (0.1–0.4) | 0.2 (0.1–0.6)
Other^b^ | 1.3 (0.8–2.0) | 3.2 (2.2–4.6)
Male | 2.2 (1.3–3.6) | 6.3 (4.3–9.0)
Female | 0.3 (0.1–0.8) | 0.3 (0.1–1.1)
Age (in years)
12–13 | 0.4 (0.3–0.7) | NA
14–15 | 1.7 (1.4–2.1) | NA
16–17 | 4.0 (3.5–4.5) | NA
18–20 | NA | 5.4 (4.8–6.0)
21–23 | NA | 5.7 (5.1–6.4)
24–25 | NA | 5.5 (4.7–6.3)
Poverty status
At or above poverty level | 2.2 (2.0–2.5) | 6.2 (5.7–6.7)
Below poverty level | 1.5 (1.1–2.1) | 3.9 (3.3–4.6)
Unknown^c^ | NA | 5.7 (3.2–10.0)
Region
Northeast | 1.4 (1.1–1.9) | 4.1 (3.5–4.9)
Midwest | 2.7 (2.3–3.1) | 7.6 (6.7–8.6)
South | 2.5 (2.0–3.0) | 6.2 (5.5–6.9)
West | 1.3 (1.0–1.8) | 3.7 (3.0–4.5)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval; NA = not applicable.

a Current smokeless tobacco use is defined as using smokeless tobacco in the 30 days preceding the survey.

b Includes Asian, American Indian or Alaska Native, Native Hawaiian or Other Pacific Islander, and persons of 2 or more races.

c Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

Patterns of smokeless tobacco use among young adults (18–25 years of age) usually mirrored those of youth (12–17 years of age). The overall prevalence was 5.5% (Table 13.10), and current use was far more common among males (10.5%) than females (0.5%). In addition, Whites had a significantly higher prevalence of use than Blacks, Hispanic, or “Other” young adults. The prevalence of current use varied little by age among young adults. However, the higher rates for young adults compared with youth are notable. By region, the highest rate of current use among young adults was in the Midwest.

#### Current Prevalence Among Adults

In 2012, according to NSDUH, the national prevalence of current smokeless tobacco use was 3.6% for all adults (i.e., men and women 18 years of age or older) (Table 13.11). Current use was substantially higher among males (7.1%) than females (0.4%). This significant difference by gender was found for Whites, Hispanics, American Indians/Alaska Natives, and Asians. In addition, there were significant gender differences for every category within educational attainment, age, and poverty status. Because of the extremely low rates of use among females, the patterns by demographic characteristics described below will cover males only. Among racial/ethnic groups, use was highest among American Indians/Alaska Natives (16.2%), a finding that was reported previously (CDC 1987; Schinke et al. 1987; Kaplan et al. 1997). In addition, the use of smokeless tobacco was significantly higher among Whites (9.3%) than Blacks, Hispanics, or Asians. A higher prevalence was found in the groups that were not college graduates. The lowest was among those 65 years of age or older (1.5%). By region, the highest rate of use was in the Midwest and the South.

Table 13.11 Prevalence of current smokeless tobacco use^a^ among adults 18 years of age and older, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | Male % (95% CI) | Female % (95% CI) | Total % (95% CI)
Total | 7.1 (6.6–7.6) | 0.4 (0.3–0.6) | 3.6 (3.4–3.9)
Race/ethnicity
White, non-Hispanic | 9.3 (8.7–10.0) | 0.3 (0.2–0.4) | 4.7 (4.3–5.0)
Black, non-Hispanic | 2.3 (1.4–4.0) | 1.6 (0.7–3.4) | 1.9 (1.2–3.0)
Hispanic | 2.3 (1.6–3.3) | 0.1 (0.0–0.5) | 1.2 (0.9–1.7)
American Indian/Alaska Native, non-Hispanic | 16.2 (10.7–23.7) | 2.6 (1.2–5.6) | 9.3 (6.3–13.5)
Asian, non-Hispanic | 0.9 (0.4–1.9) | 0.0 (0.0–0.1) | 0.4 (0.2–0.9)
Education
Less than high school | 6.4 (5.4–7.6) | 1.4 (0.7–3.0) | 4.0 (3.3–4.8)
High school graduate | 8.7 (7.7–9.7) | 0.3 (0.2–0.6) | 4.4 (3.9–4.9)
Some college | 8.5 (7.5–9.5) | 0.3 (0.1–0.5) | 3.9 (3.5–4.4)
College graduate | 4.7 (4.0–5.5) | 0.1 (0.1–0.3) | 2.3 (2.0–2.7)
Age group (years)
18–25 | 10.5 (9.8–11.3) | 0.5 (0.4–0.7) | 5.5 (5.1–5.9)
26–44 | 9.9 (8.9–10.9) | 0.3 (0.2–0.5) | 5.0 (4.6–5.6)
45–64 | 5.0 (4.2–5.9) | 0.3 (0.2–0.7) | 2.6 (2.2–3.1)
≥65 | 2.7 (1.9–3.8) | 0.6 (0.2–1.8) | 1.5 (1.0–2.1)
Poverty status
At or above poverty level | 7.2 (6.7–7.7) | 0.3 (0.1–0.5) | 3.7 (3.4–4.0)
Below poverty level | 6.5 (5.4–7.8) | 1.0 (0.6–1.8) | 3.2 (2.7–3.9)
Unknown^b^ | 11.1 (6.1–19.2) | 0.2 (0.1–0.8) | 5.7 (3.2–10.0)
Region
Northeast | 4.2 (3.5–4.9) | 0.2 (0.1–0.3) | 2.1 (1.7–2.4)
Midwest | 9.0 (8.0–10.1) | 0.5 (0.2–1.5) | 4.6 (4.1–5.3)
South | 8.4 (7.6–9.4) | 0.5 (0.3–0.9) | 4.3 (3.9–4.8)
West | 5.5 (4.5–6.6) | 0.3 (0.1–0.5) | 2.8 (2.4–3.3)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval.

a Current smokeless tobacco use is defined as using smokeless tobacco in the 30 days preceding the survey.

b Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

#### Trends Over Time in the Use of Smokeless Tobacco

Figure 13.18 shows trend data on the use of smokeless tobacco among youth from 1995–2011 that were derived from the National YRBS. Data on use of smokeless tobacco were first measured by YRBS in 1995, but data from other surveys indicate that the use of smokeless tobacco among youth rose sharply in the early 1990s and peaked around 1995 (USDHHS 2012). As shown in Figure 13.18A, the use of smokeless tobacco by female students was very low throughout the 1995–2011 period. Among male students, use declined from 1995–2003, and was stable from 2003–2011. Use differed by race/ethnicity with White male students having consistently higher rates of use than their Hispanic or Black counterparts (Figure 13.18B). However, due to a decrease in smokeless tobacco use among White males from 1995–2003, the gap between White male students and Black and Hispanic male students has decreased over time. As revealed in Figure 13.18B, the use of smokeless tobacco among Black and Hispanic male students was stable from 1995–2011.

Figure 13.18 Trends over time in prevalence (%) of current smokeless tobacco use among high school students, by gender and race/ethnicity (males only); National Youth Risk Behavior Survey (YRBS) 1995–2011; United States

Source: 1995–2011 National YRBS: Centers for Disease Control and Prevention.

Note: Based on responses to the question “During the past 30 days, on how many days did you use chewing tobacco, snuff, or dip, such as Red Man, Levi Garrett, Beech Nut, Skoal, Skoal Bandits, or Copenhagen?” Respondents who reported that they used chewing tobacco, snuff, or dip on at least 1 day during the 30 days before the survey were classified as current smokeless tobacco users.

Part A Line graph shows that from 1995 to 2011 the prevalence of current smokeless tobacco use among U.S. high school students decreased somewhat in males (from 19 percent in 1995 to 12 percent in 2011) but remained relatively unchanged in females (from nearly 2.5 percent in 1995 to slightly more than 2 percent in 2011). Part B Line graph shows that from 1995 to 2011 the prevalence of current smokeless tobacco use among U.S. male high school students decreased moderately among White, non-Hispanic males (from 14 percent in 1995 to 9 percent in 2011) but increased slightly among Black, non-Hispanic males (from 2 percent in 1995 to 3 percent in 2011) and Hispanic males (4 percent in 1995 to nearly 6 percent in 2011).

Figure 13.19 Trends in prevalence (%) of smokeless tobacco usea among adults 18 years of age and older, by gender and selected survey yearsb; National Health Interview Survey (NHIS) 1987–2010; United States

^a^ Current users of smokeless tobacco included respondents who reported currently using snuff or chewing tobacco. From 1987 to 1992, this group included those who reported ever using snuff or chewing tobacco or using snuff or chewing tobacco at least 20 times and who specified currently using snuff or chewing tobacco. In 1998, this group included those who reported using snuff or chewing tobacco at least 20 times and who specified currently using snuff or chewing tobacco every day or some days. From 2000 to 2010, this category included those who reported ever using snuff or chewing tobacco or using snuff or chewing tobacco at least 20 times and who specified currently using snuff or chewing tobacco every day or some days.

^b^ Data are plotted for 1987, 1991, 1992, 1998, 2000, 2005, and 2010.

Source: 1987–2010 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1987 to 2010 the prevalence of current smokeless tobacco use among U.S. adults, 18 years of age and older, decreased marginally in males (from nearly 6 percent in 1987 to 5 percent in 2010) and females (from 0.6 percent in 1987 to 0.2 percent in 2010).

Trend data on the use of smokeless tobacco among adults have been derived from the NHIS; questions on smokeless tobacco use were asked on that survey in 1987, 1991, 1992, 1998, 2000, 2005, and 2010. Across these years (Figure 13.19), use was extremely low among females. For males, prevalence decreased from 1986–2000 but has been increasing since then. Concerning race/ethnicity, a decrease followed by an increase was seen for White males who have had, historically, higher rates of current use of smokeless tobacco than Black or Hispanic males. The prevalence among Black and Hispanic males (Figure 13.20) varied over time, but the erratic trend line among Hispanics should be viewed with caution, given the small sample. Last, three of the four male age groups (i.e., all but the 25–44 years of age group), experienced declines in the use of smokeless tobacco between 1987–2000, but an upward trend was documented for males 18–24 years of age beginning in 2000 and in the other three age groups from 2005 (Figure 13.21).

Figure 13.20 Trends in prevalence (%) of smokeless tobacco usea among adult males 18 years of age and older, by race/ethnicityb and selected survey yearsc; National Health Interview Survey (NHIS) 1987–2010; United States

^a^ Current users of smokeless tobacco included respondents who reported currently using snuff or chewing tobacco. From 1987 to 1992, this group included those who reported ever using snuff or chewing tobacco or using snuff or chewing tobacco at least 20 times and who specified currently using snuff or chewing tobacco. In 1998, this group included those who reported using snuff or chewing tobacco at least 20 times and who specified currently using snuff or chewing tobacco every day or some days. From 2000 to 2010, this category included those who reported ever using snuff or chewing tobacco or using snuff or chewing tobacco at least 20 times and who specified currently using snuff or chewing tobacco every day or some days.

^b^ In 1999, NHIS began reporting race according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity. Before 1999, data were reported according to the 1977 Standards and thus are not strictly comparable to later years. In 2000, NHIS began reporting Hispanic ethnicity (which includes persons of Hispanic, Latino, or Spanish descent).

^c^ Data are plotted for 1987, 1991, 1992, 1998, 2000, 2005, and 2010.

Source: 1987–2010 NHIS, National Center for Health Statistics, public use data tapes.

^d^ Data for Hispanics were statistically unreliable (relative standard error >30%) for 1987, 1992, 2000, and 2005.

Line graph shows that from 1997 to 2010 the prevalence of current smokeless tobacco use among U.S. adults, 18 years of age and older, increased slightly among White, non-Hispanics (from 6.5 percent in 1987 to slightly more than 7 percent in 2010), decreased substantially among Black, non-Hispanics (from more than 4.5 percent in 1987 to 1.5 percent in 2010), and decreased slightly among Hispanics (from more than 1.5 percent in 1991 to less than one percent in 2010).

Figure 13.21 Trends in prevalence (%) of smokeless tobacco usea among adult males 18 years of age and older, by age group and selected survey yearsb; National Health Interview Survey (NHIS) 1987–2010; United States

^a^ Current users of smokeless tobacco included respondents who reported currently using snuff or chewing tobacco. From 1987 to 1992, this group included those who reported ever using snuff or chewing tobacco or using snuff or chewing tobacco at least 20 times and who specified currently using snuff or chewing tobacco. In 1998, this group included those who reported using snuff or chewing tobacco at least 20 times and who specified currently using snuff or chewing tobacco every day or some days. From 2000 to 2010, this category included those who reported ever using snuff or chewing tobacco or using snuff or chewing tobacco at least 20 times and who specified currently using snuff or chewing tobacco every day or some days.

^b^ Data are plotted for 1987, 1991, 1992, 1998, 2000, 2005, and 2010.

Source: 1987–2010 NHIS, National Center for Health Statistics, public use data tapes.

Line graph shows that from 1987 to 2010 the prevalence of smokeless tobacco use among U.S. adult males, 18 years of age and older, was lower in three or four age groups in 2010 compared with 2007: 18–24 years of age (from more than 7.5 percent in 1987 to nearly 7 percent in 2010), 45–64 years of age (from 5.5 percent in 1987 to more than 3.5 percent in 2010), and 65 years of age and older (from 7 percent in 1987 to nearly 4 percent in 2010). Prevalence increased moderately (from 5 percent in 1987 to nearly 7 percent in 2010) in males 25–44 years of age.

### Patterns of Cigar Use

The Excise Tax Reduction Act of 1965 defines a cigar as “any roll of tobacco wrapped in leaf tobacco or in any substance containing tobacco”. There are many different types of cigars, including large cigars, cigarillos, and small or little cigars. Small or little cigars closely resemble cigarettes. Despite the wide variety of cigar products, however, a single classification system has not been accepted universally (Baker et al. 2000). Historically, cigar smoking in the United States has been a behavior of older men, but the industry's increased marketing of cigars during the 1990s to targeted groups reversed the low rates of use among adolescents (USDHHS 1998). Correspondingly, the rise in the prevalence of cigar use during the mid-1990s was not limited to adults. Instead, as documented by numerous local, state, and national surveys, cigar use and experimentation was widespread among both male and female adolescents (CDC 1997; Delnevo et al. 2002; Marshall et al. 2006).

#### Current Prevalence Among Youth and Young Adults

NSDUH data indicate that 2.6% of 12- to 17-year-olds were current smokers of cigars in 2012 (Table 13.12), with current use defined as smoking cigars in the preceding 30 days. Use differed by gender, with males (3.5%) having smoked cigars at slightly over twice the rate of females (1.6%); this gender pattern also held for Whites, Hispanics, and others. By race/ethnicity, White youth had the highest prevalence. Current cigar use rose with increasing age.

Table 13.12 Prevalence of current cigar use^a^ among young people, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | 12–17 years of age % (95% CI) | 18–25 years of age % (95% CI)
Overall | 2.6 (2.3–2.9) | 10.7 (10.2–11.3)
Gender
Male | 3.5 (3.1–3.9) | 16.4 (15.5–17.3)
Female | 1.6 (1.4–2.0) | 5.1 (4.6–5.7)
Race/ethnicity
White, non-Hispanic | 3.2 (2.9–3.6) | 12.1 (11.4–12.9)
Male | 4.4 (3.9–5.1) | 19.0 (17.8–20.2)
Female | 1.9 (1.5–2.4) | 5.2 (4.5–5.9)
Black or African American, non-Hispanic | 1.9 (1.4–2.6) | 11.8 (10.5–13.4)
Male | 2.3 (1.6–3.3) | 15.5 (13.4–18.0)
Female | 1.5 (0.8–2.7) | 8.5 (7.0–10.2)
Hispanic or Latino | 1.8 (1.4–2.3) | 7.3 (6.3–8.5)
Male | 2.2 (1.6–3.1) | 11.6 (9.7–13.8)
Female | 1.3 (0.9–1.9) | 2.7 (2.1–3.6)
Other^b^ | 1.8 (1.2–2.7) | 8.0 (6.3–10.2)
Male | 2.6 (1.6–4.3) | 12.0 (9.0–15.7)
Female | 1.0 (0.5–1.7) | 4.2 (2.6–6.8)
Age (in years)
12–13 | 0.4 (0.2–0.6) | NA
14–15 | 1.7 (1.4–2.1) | NA
16–17 | 5.6 (5.0–6.2) | NA
18–20 | NA | 11.9 (11.1–12.8)
21–23 | NA | 10.5 (9.7–11.4)
24–25 | NA | 9.2 (8.3–10.2)
Poverty status
At or above poverty level | 2.6 (2.4–3.0) | 10.8 (10.2–11.5)
Below poverty level | 2.4 (1.9–2.9) | 10.1 (9.1–11.2)
Unknown^c^ | NA | 14.3 (11.4–17.8)
Region
Northeast | 2.8 (2.3–3.5) | 11.1 (9.8–12.5)
Midwest | 2.9 (2.5–3.4) | 11.8 (10.8–12.9)
South | 2.7 (2.2–3.2) | 11.3 (10.4–12.2)
West | 2.0 (1.6–2.6) | 8.8 (7.6–10.0)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval; NA = not applicable.

a Current cigar use is defined as smoking cigars in the 30 days preceding the survey.

b Includes Asian, American Indian or Alaska Native, Native Hawaiian or Other Pacific Islander, and persons of 2 or more races.

c Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

In 2012, 10.7% of young adults (18–25 years of age) were current cigar smokers (Table 13.12), and the patterns of use generally mirrored those of youth. Current use among males (16.4%) was over three times that of females (5.1%). Use among females, however, was not inconsequential; in fact, the estimate for Black females was 8.5% in 2012. For young adults overall, the highest prevalence by race/ethnicity was among Whites and Blacks. Notably, despite a large difference in the prevalence of cigar use between 16- to 17-year-olds (5.6%) and 18- to 20-year-olds (11.9%), the prevalence of cigar use among young adults (18–20 years of age) was significantly lower than use among 21- to 23-year-olds and 24- to 25-year-olds. Current use varied by region with the lowest prevalence in the West.

#### Current Prevalence Among Adults

For 2012, the estimated prevalence for current cigar use among adults was 5.4% (Table 13.13). The estimate for males (9.1%) was more than four times that for females (2.0%). These gender differences persisted for all racial/ethnic groups as well as by educational status, age, and poverty status, but the magnitude of the difference by gender, when expressed as a ratio, was notably less for young adults than for adults 45–64 or 65 years of age and older. By race/ethnicity, the prevalence was highest among American Indians/Alaska Natives (7.9%), followed by Blacks (7.6%), Whites (5.5%), Hispanics (4.2%), and Asians (1.7%). This pattern was fairly consistent in both genders. The prevalence of cigar use varied little by educational status, except that lower use was observed among those who were college graduates (4.6%). Age and current cigar use were inversely related, with an estimate of 10.7% for those 18–25 years of age and just 1.6% for those 65 years of age or older. Use was more likely among those living below the poverty level (6.6%) than it was for those at or above the poverty level (5.2%). It is useful to highlight here that some research suggests that when faced with higher cigarette prices as a result of increases in the cigarette excise tax, cigarette smokers switch to cigars (Delnevo et al. 2004; Delnevo and Hrywna 2007), and those living below the poverty level are more price sensitive. Regionally, the highest prevalence was in the Northeast (5.9%) and in the West (4.4%).

Table 13.13 Prevalence of current cigar use^a^ among adults 18 years of age and older, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | Male % (95% CI) | Female % (95% CI) | Total % (95% CI)
Total | 9.1 (8.5–9.7) | 2.0 (1.8–2.3) | 5.4 (5.1–5.8)
Race/ethnicity
White, non-Hispanic | 9.5 (8.8–10.3) | 1.7 (1.5–2.0) | 5.5 (5.1–5.9)
Black, non-Hispanic | 12.3 (10.4–14.5) | 3.8 (3.1–4.8) | 7.6 (6.7–8.7)
Hispanic | 6.7 (5.3–8.5) | 1.7 (1.2–2.5) | 4.2 (3.5–5.2)
American Indian/Alaska Native, non-Hispanic | –^b^ | 2.5 (1.1–5.5) | 7.9 (4.4–13.7)
Asian, non-Hispanic | 2.7 (1.4–5.4) | 0.7 (0.3–2.0) | 1.7 (0.9–2.9)
Education
Less than high school | 10.1 (8.6–11.8) | 2.8 (2.1–3.7) | 6.5 (5.7–7.5)
High school graduate | 8.4 (7.5–9.3) | 2.0 (1.6–2.4) | 5.1 (4.6–5.6)
Some college | 10.7 (9.5–12.0) | 2.3 (1.9–2.9) | 6.1 (5.5–6.7)
College graduate | 8.0 (7.0–9.2) | 1.4 (1.0–1.8) | 4.6 (4.1–5.2)
Age group (years)
18–25 | 16.4 (15.5–17.3) | 5.1 (4.6–5.7) | 10.7 (10.2–11.3)
26–44 | 10.3 (9.3–11.4) | 2.2 (1.8–2.7) | 6.2 (5.7–6.8)
45–64 | 7.6 (6.5–8.8) | 1.4 (1.0–1.9) | 4.4 (3.8–5.0)
≥65 | 3.1 (2.2–4.4) | 0.5 (0.2–1.1) | 1.6 (1.2–2.2)
Poverty status
At or above poverty level | 8.6 (8.0–9.3) | 1.8 (1.5–2.0) | 5.2 (4.8–5.5)
Below poverty level | 11.6 (10.2–13.3) | 3.1 (2.5–3.9) | 6.6 (5.9–7.4)
Unknown^c^ | 23.3 (17.8–29.8) | 5.2 (3.4–7.8) | 14.3 (11.4–17.8)
Region
Northeast | 10.2 (8.8–11.7) | 1.9 (1.4–2.5) | 5.9 (5.1–6.7)
Midwest | 9.2 (8.2–10.3) | 2.3 (1.9–2.8) | 5.6 (5.1–6.2)
South | 9.6 (8.6–10.7) | 2.2 (1.8–2.6) | 5.7 (5.2–6.3)
West | 7.4 (6.3–8.8) | 1.6 (1.2–2.1) | 4.4 (3.8–5.2)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval.

a Current cigar use is defined as smoking cigars in the 30 days preceding the survey.

b Low precision; no estimate reported.

c Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

#### Trends Over Time in the Use of Cigars

Data from 1997–2011 obtained from the National YRBS indicate that current cigar use among male high school students declined from 1997–2005 and then remained stable from 2005–2011 (Figure 13.22A). Among female students, current cigar use declined from 1997–2011. Current use declined among all three racial/ethnic groups presented in Figure 13.22B. Among White students, current cigar use declined from 1997–2003 and then remained stable from 2003–2011. Among Black students, current cigar use declined from 1997–2007 and then remained stable from 2007–2011. Among Hispanic students, current cigar use declined from 1997–2011.

Figure 13.22 Trends over time in prevalence (%) of current cigar smoking among high school students, by gender and race/ethnicity; National Youth Risk Behavior Survey (YRBS) 1997–2011; United States

Source: 1997–2011 National YRBS: Centers for Disease Control and Prevention.

Note: Based on responses to the question “During the past 30 days, on how many days did you smoke cigars, cigarillos, or little cigars?” Respondents who reported that they had smoked cigars, cigarillos, or little cigars on at least 1 day during the 30 days before the survey were classified as current cigar users.

Part A Line graph shows that from 1997 to 2011 the prevalence of current cigar smoking among U.S. high school students decreased dramatically for males (from 31 percent in 1997 to less than 18 percent in 2011) but only slightly for females (from more than 10.5 percent in 1997 to 8 percent in 2011). Part B Line graph shows that from 1997 to 2011 the prevalence of current cigar use among U.S. high school students decreased by race/ethnicity: White, non-Hispanics (from 22.5 percent in 1997 to 13.5 percent in 2011); Black, non-Hispanics (from more than 19 percent in 1997 to less than 12 percent in 2011); and Hispanics (from 20 percent in 1997 to 13.5 percent in 2011).

Trend data on adult cigar smoking are derived from NHIS; questions on cigar use were asked on that survey in 1987, 1991, 1992, 1998, 2000, 2005, and 2010. Per Figure 13.23, the prevalence of cigar use was extremely low among females across the period of interest. Among adult males, prevalence decreased from 1986–1992, then increased through 1998 and was essentially stable thereafter. When examined by racial/ethnic groups (Figure 13.24), there was no clear trend among Hispanic and Black non-Hispanic males. Figure 13.25 highlights trends in adult male cigar use by age groups. Cigar use declined among all age groups from 1987–1992 and then began to rise for all groups, except those 65 years of age and older. The increase peaked in 1998 and then remained relatively flat through 2010 for 18- to 24-year-olds and 25- to 44-year-olds. However, cigar use among 45- to 64-year-olds increased slightly from 1998–2010.

Figure 13.23 Trends in prevalence (%) of current cigar usea among adults 18 years of age and older, by gender and selected survey yearsb; National Health Interview Survey (NHIS) 1987–2010; United States

^a^ Current users of cigars included respondents who reported currently using cigars. From 1987 to 1992, this group included those who reported ever smoking cigars and who specified smoking cigars now. From 1998 to 2010, this group included those who reported ever smoking cigars and who specified currently smoking cigars every day or some days.

^b^ Data are plotted for 1987, 1991, 1992, 1998, 2000, 2005, and 2010.

Source: 1987–2010 NHIS, National Center for Health Statistics, public use data tapes.

^c^ Data for females were statistically unreliable (relative standard error >30%) for 1987, 1991, and 1992.

Line graph shows that from 1987 to 2010 the percentage of current cigar use among U.S. adults fluctuated among males and rose slightly among females. For males, prevalence of current cigar use fluctuated during the period but was higher in 1987 (more than 5.5 percent) than 2010 (more than 4.5 percent). For females, prevalence rose slightly from 0.2 percent in 1998 to 0.5 percent in 2010.

Figure 13.24 Trends in prevalence (%) of current cigar usea among adult males 18 years of age and older, by race/ethnicityb and selected survey yearsc; National Health Interview Survey (NHIS) 1987–2010; United States

^a^ Current users of cigars included respondents who reported currently using cigars. From 1987 to 1992, this group included those who reported ever smoking cigars or smoking at least 50 cigars and who specified smoking cigars now. From 1998 to 2010, this category included those who reported ever smoking cigars or smoking at least 50 cigars and who specified currently smoking cigars every day or some days.

^b^ In 1999, NHIS began reporting race according to the 1997 Revisions to the Standards for the Classification of Federal Data on Race and Ethnicity. Before 1999, data were reported according to the 1977 Standards and thus are not strictly comparable to later years. In 2000, NHIS began reporting Hispanic ethnicity (which includes persons of Hispanic, Latino, or Spanish descent).

^c^ Data are plotted for 1987, 1991, 1992, 1998, 2000, 2005, and 2010.

Source: 1987–2010 NHIS, National Center for Health Statistics, public use data tapes.

^d^ Data for Hispanics were statistically unreliable (relative standard error >30%) for 1992.

Line graph shows that from 1987 to 2010 the prevalence of current cigar use among U.S. adult males varied by race/ethnicity. Cigar use was consistently highest among White, non-Hispanics, and Black, non-Hispanics was the only population in which prevalence was higher in 2010 than in 2007. Prevalence generally dipped across all three groups into the early 1990s and then fluctuated through 2010: White, non-Hispanics (from 6 percent in 1987 to nearly 5.5 percent in 2010); Black, non-Hispanics (from 4 percent in 1987 to nearly 5 percent in 2010); and Hispanics (from nearly 4.5 percent in 1987 to less than 2.5 percent in 2010).

Figure 13.25 Trends in prevalence (%) of current cigar usea among adult males 18 years of age and older, by age group and selected survey yearsb, National Health Interview Survey (NHIS) 1987–2010; United States

^a^ Current users of cigars included respondents who reported currently using cigars. From 1987 to 1992, this group included those who reported ever smoking cigars or smoking at least 50 cigars and who specified smoking cigars now. From 1998 to 2010, this category included those who reported ever smoking cigars or smoking at least 50 cigars and who specified currently smoking cigars every day or some days.

^b^ Data are plotted for 1987, 1991, 1992, 1998, 2000, 2005, and 2010.

Source: 1987–2010 NHIS, National Center for Health Statistics, public use data tapes.

^c^ Data for adults 18–24 years of age were statistically unreliable (relative standard error >30%) for 1992.

Line graph shows that from 1987 to 2010 current cigar use among U.S. adult males, 18 years of age and older, fluctuated in general but increased modestly for the youngest age group and decreased slightly for three oldest age groups: 18–24 years of age (from more than 1.5 percent in 1987 to more than 3.5 percent in 2010), 25–44 years of age (from more than 6 percent in 1987 to less than 4.5 percent in 2010), 45–64 years of age (from 7.5 percent in 1987 to 6 percent in 2010), and 65 years of age and older (from nearly 5 percent in 1987 to 3.5 percent in 2010).

### Patterns of Polytobacco Use

The use of multiple tobacco products—also called polytobacco use, dual use, or concurrent use—is common among some tobacco users (Backinger et al. 2008). In 2012, per NSDUH (Table 13.14), an estimated 8.6% of youth (12–17 years of age), 38.1% of young adults, and 27.0% of adults (26 years of age or older) were current users of one or more tobacco products. Most users used only one tobacco product (predominantly cigarettes), but 2.6% of youth, 10.1% of young adults, and 3.7% of adults used more than one product. The most common combination in all three age groups was cigarettes and cigars; for roughly one-half of polytobacco users, this was the combination employed.

Table 13.14 Prevalence of current use of multiple tobacco products by age group; National Survey on Drug Use and Health (NSDUH) 2012; United States

Tobacco products^a^ | 12–17 years of age % (95% CI) | 18–25 years of age % (95% CI) | ≥26 years of age % (95% CI)
No tobacco use | 91.4 (90.9–91.8) | 61.9 (61.0–62.9) | 73.0 (72.2–73.8)
User, any tobacco products | 8.6 (8.2–9.1) | 38.1 (37.1–39.0) | 27.0 (26.2–27.8)
Cigarettes only | 4.1 (3.8–4.5) | 22.5 (21.7–23.3) | 19.0 (18.3–19.8)
Smokeless tobacco only | 0.9 (0.7–1.0) | 1.7 (1.5–2.0) | 2.0 (1.8–2.3)
Cigars only | 0.8 (0.7–1.0) | 3.4 (3.1–3.7) | 1.9 (1.7–2.2)
Pipe only | 0.2 (0.1–0.3) | 0.4 (0.3–0.6) | 0.3 (0.2–0.4)
Multiple tobacco products | 2.6 (2.4–2.9) | 10.1 (9.6–10.6) | 3.7 (3.4–4.0)
Cigarettes + smokeless only | 0.6 (0.5–0.8) | 2.1 (1.9–2.3) | 0.8 (0.7–0.9)
Cigarettes + cigars only | 1.1 (0.9–1.2) | 5.1 (4.7–5.5) | 2.0 (1.8–2.2)
Cigarettes + pipe only | 0.2 (0.1–0.3) | 0.5 (0.4–0.6) | 0.2 (0.2–0.3)
Smokeless + cigars only | 0.1 (0.1–0.2) | 0.5 (0.4–0.6) | 0.2 (0.1–0.3)
Smokeless + pipe only | –^b^ | 0.0 (0.0–0.1) | 0.0 (0.0–0.1)
Cigars + pipe only | 0.0 (0.0–0.1) | 0.2 (0.1–0.3) | 0.1 (0.1–0.2)
Cigarettes + smokeless + cigars only | 0.3 (0.2–0.4) | 1.0 (0.9–1.2) | 0.2 (0.1–0.2)
Cigarettes + smokeless + pipe only | 0.0 (0.0–0.1) | 0.0 (0.0–0.1) | 0.1 (0.0–0.2)
Cigarettes + cigars + pipe only | 0.1 (0.1–0.2) | 0.5 (0.4–0.6) | 0.1 (0.1–0.2)
Cigars + smokeless + pipe only | 0.0 (0.0–0.0) | 0.0 (0.0–0.0) | –^b^
Cigarettes + cigars + smokeless + pipe | 0.1 (0.0–0.1) | 0.1 (0.1–0.2) | 0.0 (0.0–0.0)

Source: 2012 NSDUH: Substance Abuse and Mental Health Administration.

Note: CI = confidence interval.

a Tobacco products include cigarettes, smokeless tobacco (i.e., chewing tobacco and snuff), cigars, and pipe tobacco.

b Low precision; no estimate reported.

#### Current Prevalence Among Youth and Young Adults

Among youth, polytobacco use in 2012 (Table 13.15) was higher among males (3.7%) than females (1.5%), primarily because smokeless tobacco and cigar use are more common among males. Polytobacco use was higher among White youth (3.6%) than Hispanic (1.6%) or Black (1.1%) youth. Consistent with other prevalence trends, polytobacco use increased with age. No discernible trend was observed by region.

Table 13.15 Prevalence of current use of multiple tobacco products^a^ among young people, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | 12–17 years of age % (95% CI) | 18–25 years of age % (95% CI)
Overall | 2.6 (2.4–2.9) | 10.1 (9.6–10.6)
Gender
Male | 3.7 (3.3–4.1) | 16.1 (15.3–17.0)
Female | 1.5 (1.2–1.8) | 3.9 (3.5–4.4)
Race/ethnicity
White, non-Hispanic | 3.6 (3.2–4.0) | 12.7 (12.0–13.5)
Male | 5.2 (4.6–5.9) | 20.7 (19.5–21.9)
Female | 1.9 (1.5–2.3) | 4.7 (4.1–5.4)
Black or African American, non-Hispanic | 1.1 (0.7–1.8) | 6.8 (5.7–8.0)
Male | 1.3 (0.7–2.3) | 9.6 (7.8–11.7)
Female | 0.9 (0.4–2.0) | 4.2 (3.1–5.7)
Hispanic or Latino | 1.6 (1.2–2.1) | 5.8 (4.8–6.8)
Male | 2.1 (1.5–2.9) | 9.4 (7.8–11.3)
Female | 1.1 (0.8–1.7) | 1.8 (1.3–2.6)
Other^b^ | 1.4 (0.9–2.2) | 8.1 (6.3–10.4)
Male | 1.9 (1.0–3.4) | 13.1 (9.9–17.0)
Female | 0.9 (0.5–1.7) | 3.4 (1.9–6.0)
Age (in years)
12–13 | 0.5 (0.3–0.7) | NA
14–15 | 1.7 (1.4–2.1) | NA
16–17 | 5.5 (4.9–6.1) | NA
18–20 | NA | 10.6 (9.8–11.5)
21–23 | NA | 10.2 (9.4–11.0)
24–25 | NA | 9.0 (8.0–10.0)
Poverty status
At or above poverty level | 2.7 (2.4–3.0) | 10.4 (9.8–11.0)
Below poverty level | 2.5 (1.9–3.1) | 9.1 (8.2–10.2)
Unknown^c^ | NA | 11.3 (8.2–15.3)
Region
Northeast | 1.8 (1.4–2.3) | 9.3 (8.1–10.5)
Midwest | 3.1 (2.7–3.6) | 11.7 (10.6–12.8)
South | 3.0 (2.5–3.6) | 11.0 (10.2–11.9)
West | 2.1 (1.7–2.7) | 7.8 (6.8–8.9)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval; NA = not applicable.

a Multiple use is defined as using 2 or more tobacco products. Tobacco products include cigarette, smokeless tobacco (i.e., chewing tobacco and snuff), cigars, and pipe tobacco.

b Includes Asian, American Indian or Alaska Native, Native Hawaiian or Other Pacific Islander, and persons of 2 or more races.

c Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

The prevalence of polytobacco use among young adults (18–25 years of age) was four times that of youth (Table 13.15). Among young adults, the difference between males (16.1%) and females (3.9%) was more pronounced than it was among youth. Racial/ethnic differences in polytobacco use mirrored that of youth. Moreover, polytobacco use was higher among White young adult males (20.7%) than any other group. Use of more than one tobacco product was highest at 18–20 years of age (10.6%) and 21–23 years of age (10.2%). Regionally, the highest prevalence of polytobacco use was observed in the Midwest and South.

#### Current Prevalence Among Adults

Among adults (18 years of age or older), the prevalence of polytobacco use in 2012 was much higher among males (7.9%) than females (1.6%) (Table 13.16). The prevalence varied by race/ethnicity. It was highest among American Indians/Alaska Natives (6.8%) and Blacks (5.3%) and lowest among Asians (1.0%). Polytobacco use increased as educational level decreased. The patterns by age group reflect those described previously for cigarettes, cigars, and smokeless tobacco, with prevalence inversely related to age group. Last, polytobacco use among those below the poverty level (7.0%) was almost twice that of those at or above the poverty level (4.1%).

Table 13.16 Prevalence of current use of multiple toba cco products^a^ among adults 18 years of age and older, by selected characteristics; National Survey on Drug Use and Health (NSDUH) 2012; United States

Characteristic | Male % (95% CI) | Female % (95% CI) | Total % (95% CI)
Total | 7.9 (7.4–8.4) | 1.6 (1.4–1.8) | 4.6 (4.4–4.9)
Race/ethnicity
White, non-Hispanic | 8.7 (8.1–9.3) | 1.5 (1.3–1.8) | 5.0 (4.7–5.3)
Black, non-Hispanic | 9.3 (7.6–11.3) | 2.0 (1.5–2.8) | 5.3 (4.5–6.3)
Hispanic | 4.8 (3.7–6.1) | 1.5 (1.0–2.2) | 3.1 (2.5–3.9)
American Indian/Alaska Native, non-Hispanic | 12.0 (7.3–19.2) | 1.8 (0.8–4.0) | 6.8 (4.2–10.8)
Asian, non-Hispanic | 1.1 (0.7–1.8) | 0.9 (0.4–2.3) | 1.0 (0.6–1.7)
Education
Less than high school | 10.9 (9.5–12.5) | 2.9 (2.2–3.8) | 7.0 (6.2–8.0)
High school graduate | 9.0 (8.1–10.0) | 1.5 (1.2–1.9) | 5.2 (4.7–5.7)
Some college | 9.1 (8.2–10.2) | 1.8 (1.4–2.2) | 5.1 (4.6–5.6)
College graduate | 4.0 (3.3–4.8) | 0.9 (0.6–1.3) | 2.4 (2.0–2.8)
Age group (years)
18–25 | 16.1 (15.3–17.0) | 3.9 (3.5–4.4) | 10.1 (9.6–10.6)
26–44 | 10.2 (9.2–11.2) | 1.8 (1.5–2.3) | 5.9 (5.4–6.5)
45–64 | 5.2 (4.3–6.3) | 1.0 (0.7–1.4) | 3.1 (2.6–3.6)
≥65 | 1.2 (0.7–1.9) | 0.5 (0.2–1.1) | 0.8 (0.5–1.2)
Poverty status
At or above poverty level | 7.0 (6.5–7.6) | 1.3 (1.1–1.5) | 4.1 (3.9–4.4)
Below poverty level | 12.8 (11.3–14.5) | 3.0 (2.3–3.7) | 7.0 (6.2–7.8)
Unknown^b^ | 19.9 (14.1–27.3) | 2.5 (1.4–4.5) | 11.3 (8.2–15.3)
Region
Northeast | 6.5 (5.6–7.4) | 1.3 (1.0–1.9) | 3.8 (3.3–4.3)
Midwest | 8.2 (7.3–9.1) | 1.9 (1.6–2.4) | 5.0 (4.5–5.5)
South | 9.5 (8.6–10.5) | 1.7 (1.4–2.1) | 5.4 (5.0–5.9)
West | 6.1 (5.1–7.3) | 1.3 (0.9–1.8) | 3.7 (3.1–4.3)

Source: 2012 NSDUH: Substance Abuse and Mental Health Services Administration.

Note: CI = confidence interval.

a Multiple use is defined as using 2 or more tobacco products. Tobacco products include cigarette, smokeless tobacco (i.e., chewing tobacco and snuff), cigars, and pipe tobacco.

b Respondents 18–22 years of age currently living in a college dormitory are included in the Unknown category.

### Patterns of New and Emerging Products Use

#### Current Prevalence Among Youth and Young Adults

An analysis of data from the 2011 and 2012 National Youth Tobacco Survey (NYTS) provided an updated definition of current tobacco use, in which hookah, snus, dissolvable tobacco, and electronic cigarettes were added to take into account nonconventional products that are either new to the market and/or are increasing in popularity. The previous definition for current tobacco use included only cigarettes, cigars, smokeless tobacco, pipes, bidis, and kreteks, thus yielding slightly lower estimates of current tobacco use. For example, in 2011, the previous definition for overall current tobacco use resulted in estimates of 7.1% for middle school and 23.2% for high school students, whereas the new definition resulted in 2011 estimates of 7.5% for middle school and 24.3% for high school students (Tables 13.17–13.18). In 2012, the prevalence of current tobacco use among middle and high school students was 6.7% and 23.3%, respectively. After cigarettes, cigars were the second most commonly used tobacco product at 2.8% and 12.6%, respectively.

Table 13.17 Percent current use^a^ of tobacco by product, school level, and gender, National Youth Tobacco Survey 2011 and 2012, United States

A. Middle School
| Total, 2011: % (95% CI) | Total, 2012; % (95% CI) | Females, 2011; % (95% CI) | Females, 2012; % (95% CI) | Males, 2011; % (95% CI) | Males, 2012; % (95% CI)
Tobacco^b^ | 7.5 (6.5–8.8) | 6.7 (5.8–7.7) | 5.9 (4.7–7.4) | 5.6 (4.7–6.7) | 9.0 (7.9–10.3) | 7.8 (6.7–9.0)
Both combustible & noncombustible tobacco^c^ | 1.9 (1.5–2.5) | 2.0 (1.6–2.5) | 1.6 (1.2–2.1)^*^ | 1.6 (1.2–2.1)^*^ | 2.2 (1.7–3.0) | 2.5 (2.0–3.1)
Only combustible^d^ | 4.5 (3.7–5.5) | 3.7 (3.2–4.3) | 3.8 (2.8–5.0) | 3.5 (2.8–4.4) | 5.2 (4.3–6.2)^†^ | 3.9 (3.4–4.5)^†^
Only noncombustible | 1.1 (0.8–1.4) | 1.0 (0.7–1.3) | 0.5 (0.3–0.9) | 0.5 (0.3–0.8) | 1.6 (1.2–2.3) | 1.4 (1.0–2.0)
Cigarettes | 4.3 (3.5–5.2) | 3.5 (2.8–4.3) | 4.0 (3.1–5.2) | 3.2 (2.5–4.0) | 4.5 (3.7–5.5) | 3.8 (3.0–4.7)
Cigars | 3.5 (2.8–4.2) | 2.8 (2.4–3.4) | 2.5 (1.9–3.4) | 2.4 (1.9–3.2) | 4.3 (3.4–5.4) | 3.2 (2.7–3.8)
Smokeless tobacco | 2.2 (1.8–2.7) | 1.7 (1.3–2.1) | 1.4 (1.0–2.0) | 1.2 (0.8–1.6) | 3.0 (2.3–3.8) | 2.2 (1.7–2.9)
Pipes | 2.2 (1.7–2.9) | 1.8 (1.4–2.3) | 1.8 (1.3–2.5) | 1.7 (1.3–2.3) | 2.7 (2.1–2.5) | 1.9 (1.4–2.4)
Bidis | 1.7 (1.3–2.2)^†^ | 0.6 (0.5–0.7)^†^ | 1.4 (1.0–1.9)^†^ | 0.4 (0.3–0.7)^†^ | 1.9 (1.4–2.6)^†^ | 0.7 (0.5–1.0)^†^
Kreteks | 1.1 (0.9–1.4)^†^ | 0.5 (0.4–0.7)^†^ | 0.9 (0.6–1.3)^†^ | 0.4 (0.3–0.7)^†^ | 1.3 (1.0–1.6)^†^ | 0.6 (0.4–0.9)^†^
Hookah | 1.0 (0.8–1.4) | 1.3 (1.0–1.7) | 1.0 (0.6–1.6) | 1.0 (0.7–1.4) | 1.1 (0.7–1.5) | 1.5 (1.1–2.2)
Snus | 0.9 (0.6–1.2) | 0.8 (0.6–1.0) | 0.8 (0.5–1.2) | 0.6 (0.4–0.9) | 1.0 (0.6–1.4) | 1.0 (0.7–1.4)
Dissolvable tobacco | 0.3 (0.2–0.4)^*^ | 0.5 (0.4–0.8)^*^ | 0.3 (0.2–0.5)^*^ | 0.4 (0.2–0.6)^*^ | 0.3 (0.1–0.5)^*^ | 0.7 (0.4–1.1)^*^
Electronic cigarettes | 0.6 (0.4–0.9)^†^ | 1.1 (0.9–1.5)^†^ | 0.4 (0.2–0.7)^†^ | 0.8 (0.6–1.1)^†^ | 0.7 (0.4–1.3)^†^ | 1.5 (1.1–2.1)^†^

B. High school
| Total, 2011: % (95% CI) | Total, 2012; % (95% CI) | Females, 2011; % (95% CI) | Females, 2012; % (95% CI) | Males, 2011; % (95% CI) | Males, 2012; % (95% CI)
Tobacco^b^ | 24.3 (22.1–26.6) | 23.3 (21.6–25.2) | 19.0 (17.0–21.1) | 18.1 (16.2–20.1) | 29.4 (26.6–32.4) | 28.3 (26.2–30.6)
Both combustible & noncombustible tobacco^c^ | 6.2 (5.1–7.5) | 6.8 (5.9–7.9) | 2.0 (1.5–2.6)^†^ | 3.4 (2.8–4.2)^†^ | 10.3 (8.4–12.4) | 10.1 (8.6–11.7)
Only combustible^d^ | 15.7 (14.6–16.8) | 14.4 (13.2–15.6) | 16.3 (14.4–18.3) | 14.2 (12.6–15.9) | 15.0 (13.8–16.3) | 14.6 (13.3–15.9)
Only noncombustible^e^ | 2.4 (1.8–3.2) | 2.1 (1.7–2.7) | 0.7 (0.4–1.1) | 0.5 (0.3–0.7) | 4.1 (3.1–5.5) | 3.7 (2.9–4.8)
Cigarettes | 15.8 (13.7–18.1) | 14.0 (12.5–15.7) | 13.8 (11.7–16.2) | 11.7 (10.2–13.4) | 17.7 (15.2–20.4) | 16.3 (14.5–18.3)
Cigars | 11.6 (10.5–12.7) | 12.6 (11.4–13.9) | 7.4 (6.3–8.6) | 8.4 (7.2–9.8) | 15.7 (14.3–17.2) | 16.7 (15.0–18.5)
Smokeless tobacco | 7.3 (5.9–9.0) | 6.4 (5.5–7.5) | 1.6 (1.2–2.2) | 1.5 (1.1–2.1) | 12.9 (10.4–15.9) | 11.2 (9.5–13.0)
Pipes | 4.0 (3.4–4.6) | 4.5 (4.0–5.2) | 2.8 (2.2–3.4) | 3.2 (2.7–3.9) | 5.1 (4.3–6.0) | 5.8 (5.0–6.7)
Bidis | 2.0 (1.6–2.5)^†^ | 0.9 (0.7–1.1)^†^ | 1.0 (0.7–1.4)^†^ | 0.5 (0.3–0.7)^†^ | 2.9 (2.3–3.7)^†^ | 1.3 (1.0–1.7)^†^
Kreteks | 1.7 (1.4–2.0)^†^ | 1.0 (0.8–1.2)^†^ | 0.8 (0.6–1.2)^†^ | 0.5 (0.3–0.7)^†^ | 2.4 (1.9–2.9)^†^ | 1.5 (1.1–1.9)^†^
Hookah | 4.1 (3.4–5.0)^†^ | 5.4 (4.6–6.3)^†^ | 3.5 (2.8–4.4) | 4.5 (3.7–5.4) | 4.8 (3.7–6.1) | 6.2 (5.3–7.3)
Snus | 2.9 (2.3–3.7) | 2.5 (2.0–3.0) | 0.8 (0.5–1.1) | 0.9 (0.7–1.3) | 5.1 (3.9–6.6) | 3.9 (3.2–4.9)
Dissolvable tobacco | 2.0 (1.6–2.5)^†^ | 0.8 (0.6–1.0)^†^ | 0.1 (0.1–0.4)^*^ | 0.6 (0.4–0.9)^*^ | 0.6 (0.4–1.0) | 1.0 (0.8–1.4)
Electronic cigarettes | 1.5 (1.2–2.0)^†^ | 2.8 (2.3–3.5)^†^ | 0.7 (0.5–1.0)^†^ | 1.9 (1.5–2.4)^†^ | 2.3 (1.7–3.1)^†^ | 3.7 (2.9–4.8)^†^

Source: National Youth Tobacco Survey 2011–2012.

Note: CI = confidence interval.

a Current use of cigarettes was determined by asking, “During the past 30 days, on how many days did you smoke cigarettes?”; Current use of cigars was determined by asking, “During the past 30 days, on how many days did you smoke cigars, cigarillos, or little cigars?”; Current use of smokeless tobacco was determined by asking, “During the past 30 days, on how many days did you use chewing tobacco, snuff, or dip?”; Current use of pipe was determined by asking, “During the past 30 days, on how many days did you smoke tobacco in a pipe?”; In 2011, current use of bidis and kreteks were determined by asking, “During the past 30 days, on how many days did you smoke bidis?” and “During the past 30 days, on how many days did you smoke kreteks?”; In 2012, current use of bidis and kreteks were determined by asking, “During the past 30 days, which of the following products have you used on at least one day?”; Current use of hookah, snus, dissolvable tobacco, and electronic cigarettes were deteremined by asking, “During the past 30 days, which of the following products have you used on at least one day?”

b Tobacco is use of cigarettes or cigars or smokeless tobacco or tobacco pipes or bidis or kreteks or hookah or snus or dissolvable tobacco or electronic cigarettes on >1 day in the past 30 days.

c Both combustible & noncombustible tobacco is use of cigarettes or cigars or tobacco pipes or bidis or kreteks or hookah and smokeless tobacco or snus or dissolvable tobacco or electronic cigarettes on ≥1 day in the past 30 days.

d Only combustible tobacco is use of cigarettes or cigars or tobacco pipes or bidis or kreteks or hookah on ≥1 day in the past 30 days and no use of smokeless tobacco, snus, dissolvable tobacco, and electronic cigarettes in the past 30 days.

e Only noncombustible tobacco is use of smokeless tobacco or snus or dissolvable tobacco or electronic cigarettes on ≥1 day in the past 30 days and no use of cigarettes, cigars, tobacco pipes, bidis, kreteks, and hookah in the past 30 days.

* Data statistically unreliable due to sample size <50 OR relative standard error >0.3 on at least 1 year's data; thus, no t-test was done.

† p-value of the t-test for difference between 2011 and 2012 prevalences is <0.05.

Table 13.18 Percent current use^a^ of tobacco by product, school level, and race/ethnicity, National Youth Tobacco Survey 2011 and 2012, United States

A. Middle school
| White, non-Hispanic, 2011: % (95% CI) | White, non-Hispanic, 2012: % (95% CI) | Black, non-Hispanic, 2011: % (95% CI) | Black, non-Hispanic, 2012: % (95% CI) | Other, non-Hispanic, 2011: % (95% CI) | Other, non-Hispanic, 2012: % (95% CI)
Tobacco^b^ | 6.2 (5.1–7.4) | 5.1 (4.2–6.3) | 8.5 (6.6–10.9) | 7.7 (5.9–10.1) | 11.5 (10.2–13.1) | 10.5 (8.6–12.8)
Both combustible & noncombustible tobacco^c^ | 2.0 (1.4–2.6) | 1.7 (1.3–2.2) | 0.9 (0.4–1.8)* | 1.4 (1.0–2.0)* | 2.8 (2.1–3.7) | 3.4 (2.5–4.6)
Only combustible^d^ | 3.0 (2.2–4.0) | 2.5 (2.0–3.1) | 7.0 (5.3–9.0) | 5.6 (4.3–7.3) | 7.8 (6.8–9.1)^†^ | 6.1 (4.9–7.5)^†^
Only noncombustible^e^ | 1.2 (0.8–1.7) | 1.0 (0.7–1.4) | 0.7 (0.4–1.3)* | 0.7 (0.3–2.0)* | 0.9 (0.6–1.4) | 1.0 (0.6–1.8)
Cigarettes | 3.8 (2.8–5.1) | 3.1 (2.4–4.0) | 3.6 (2.6–5.0) | 2.6 (1.7–4.0) | 6.7 (5.6–8.0) | 5.4 (4.2–7.1)
Cigars | 2.3 (1.7–3.0) | 1.6 (1.2–2.0) | 5.7 (4.3–7.4) | 5.0 (3.8–6.6) | 6.1 (4.9–7.4) | 4.9 (3.8–6.4)
Smokeless tobacco | 2.3 (1.8–2.9) | 1.6 (1.1–2.2) | 1.0 (0.5–2.1)* | 0.6 (0.3–1.3)* | 2.9 (2.3–3.6) | 2.4 (1.7–3.4)
Pipes | 1.5 (1.1–2.2) | 1.2 (0.8–1.7) | 1.3 (0.8–2.1)* | 1.2 (0.6–2.2)* | 5.0 (4.2–6.1) | 3.7 (2.7–5.1)
Bidis | 1.0 (0.7–1.5)* | 0.3 (0.2–0.5)* | 1.9 (1.1–3.2)* | 0.6 (0.4–1.0)* | 3.5 (2.6–4.6)^†^ | 1.2 (0.8–1.8)^†^
Kreteks | 0.6 (0.4–0.6) | 0.3 (0.2–0.5) | 0.9 (0.5–1.6)* | 0.2 (0.1–0.7)* | 2.5 (2.0–3.3)^†^ | 1.0 (0.6–1.7)^†^
Hookah | 0.9 (0.6–1.4) | 0.8 (0.6–1.2) | 0.9 (0.5–1.7)* | 0.9 (0.4–1.8)* | 1.7 (1.2–2.3)^†^ | 3.0 (2.2–4.1)^†^
Snus | 1.0 (0.7–1.4) | 0.7 (0.5–1.0) | 0.6 (0.2–1.3)* | 0.4 (0.1–0.9)* | 1.0 (0.6–1.5) | 1.1 (0.7–1.7)
Dissolvable tobacco | 0.2 (0.1–0.5)* | 0.4 (0.2–0.7)* | 0.4 (0.1–1.2)* | 0.5 (0.2–1.5)* | 0.2 (0.1–0.5)* | 1.0 (0.6–1.6)*
Electronic cigarettes | 0.6 (0.4–1.0)* | 0.9 (0.6–1.3)* | 0.4 (0.2–1.0)* | 1.1 (0.6–2.2)* | 0.6 (0.4–1.1)* | 2.0 (1.4–2.9)*

B. High school
| White, non-Hispanic, 2011: % (95% CI) | White, non-Hispanic, 2012: % (95% CI) | Black, non-Hispanic, 2011: % (95% CI) | Black, non-Hispanic, 2012: % (95% CI) | Other, non-Hispanic, 2011: % (95% CI) | Other, non-Hispanic, 2012: % (95% CI)
Tobacco^b^ | 26.6 (23.6–29.8) | 24.6 (22.3–27.0) | 18.9 (15.6–22.8) | 22.6 (19.7–25.8) | 23.8 (21.2–26.5) | 22.5 (19.5–25.6)
Both combustible & noncombustible tobacco^c^ | 7.5 (6.1–9.3) | 8.2 (6.9– 9.6) | 2.3 (1.2– 4.2)* | 2.3 (1.6–3.2)* | 5.4 (4.3– 6.6) | 6.4 (5.0– 8.1)
Only combustible^d^ | 15.8 (14.5–17.3)^†^ | 13.6 (12.2–15.0) † | 15.7 (13.1–18.6) | 19.2 (16.4–22.4) | 16.9 (15.2–18.3) | 14.8 (13.0–16.8)
Only noncombustible | 3.2 (2.4– 4.2) | 2.8 (2.2–3.6) | 1.0 (0.4–2.3)* | 1.1 (0.6–1.9)* | 1.5 (1.0– 2.3) | 1.3 (0.9–1.9)
Cigarettes | 17.6 (14.7– 20.9) | 15.4 (13.2–17.8) | 10.6 (7.6–14.6) | 9.6 (7.6–12.0) | 15.8 (13.9– 17.8) | 14.3 (12.0–16.9)
Cigars | 12.1 (10.7– 13.6) | 12.2 (10.8–13.8) | 11.7 (9.8–13.9) | 16.7 (14.4–19.3) | 11.3 (9.8– 13.1) | 12.4 (10.6–14.4)
Smokeless tobacco | 9.2 (7.4– 11.5) | 8.1 (6.9–9.5) | 3.0 (1.8–5.1) | 2.2 (1.5–3.2) | 5.1 (3.8– 6.8) | 5.1 (3.8–6.8)
Pipes | 3.5 (2.9– 4.4) | 4.5 (3.8–5.4) | 2.4 (1.5–3.8) | 2.9 (1.8–4.5) | 6.3 (5.2– 7.7) | 6.2 (5.2–7.4)
Bidis | 1.4 (1.0– 2.0)^†^ | 0.7 (0.5–1.0)^†^ | 2.0 (1.2–3.2)* | 0.8 (0.4–1.7)* | 3.7 (2.9– 4.8)^†^ | 1.4 (0.9–2.2)
Kreteks | 1.4 (1.0– 2.0) | 1.1 (0.8–1.5) | 1.3 (0.8–2.2)* | 0.6 (0.3–1.1)* | 2.5 (1.9– 3 3)^†^ | 0.9 (0.6–1.4)^†^
Hookah | 4.3 (3.4– 5.4)^†^ | 6.1(5.2–7.2) | 1.7 (0.9– 3.0) | 2.1 1.6–2.9) | 5.1 (4.1– 6.3) | 6.6(5.1– 8.5)
Snus | 3.7 (2.8– 4.9) | 3.3 (2.6–4.2) | 0.7 (0.3– 1.5)* | 0.6 (0.3–1.1)* | 2.3 (1.7– 3.1) | 1.8 (1.3–2.5)
Dissolvable tobacco | 0.3 (0.1– 0.5)* | 0.7 (0.5–0.9)* | 0.3 (0.1–1.2)* | 0.8 (0.4–1.3)* | 0.8 (0.5– 1.3) | 1.4(1.0– 2.1)
Electronic cigarettes | 1.8 (1.3– 2.4)^†^ | 3.4 (2.7–4.2)^†^ | 0.8 (0.3–1.7)* | 1.1 (0.7– 1.9)* | 1.3 (0.8– 2.1)^†^ | 2.7 (1.9–3.8) †

Source: National Youth Tobacco Survey 2011–2012.

Note: CI = confidence interval.

a Current use of cigarettes was determined by asking, “During the past 30 days, on how many days did you smoke cigarettes?”; Current use of cigars was determined by asking, “During the past 30 days, on how many days did you smoke cigars, cigarillos, or little cigars?”; Current use of smokeless tobacco was determined by asking, “During the past 30 days, on how many days did you use chewing tobacco, snuff, or dip?”; Current use of pipe was determined by asking, “During the past 30 days, on how many days did you smoke tobacco in a pipe?”; In 2011, current use of bidis and kreteks were determined by asking, “During the past 30 days, on how many days did you smoke bidis?” and “During the past 30 days, on how many days did you smoke kreteks?”; In 2012, current use of bidis and kreteks were determined by asking, “During the past 30 days, which of the following products have you used on at least one day?”; Current use of hookah, snus, dissolvable tobacco, and electronic cigarettes were deteremined by asking, “During the past 30 days, which of the following products have you used on at least one day?”

b Tobacco is use of cigarettes or cigars or smokeless tobacco or tobacco pipes or bidis or kreteks or hookah or snus or dissolvable tobacco or electronic cigarettes on ≥1 day in the past 30 days.

c Both combustible & noncombustible tobacco is use of cigarettes or cigars or tobacco pipes or bidis or kreteks or hookah and smokeless tobacco or snus or dissolvable tobacco or electronic cigarettes on ≥1 day in the past 30 days.

d Only combustible tobacco is use of cigarettes or cigars or tobacco pipes or bidis or kreteks or hookah on ≥1 day in the past 30 days and no use of smokeless tobacco, snus, dissolvable tobacco, and electronic cigarettes in the past 30 days.

e Only noncombustible tobacco is use of smokeless tobacco or snus or dissolvable tobacco or electronic cigarettes on ≥1 day in the past 30 days and no use of cigarettes, cigars, tobacco pipes, bidis, kreteks, and hookah in the past 30 days*.

† p-value of the t-test for difference between 2011 and 2012 prevalences is <0.05.

Data statistically unreliable due to sample size <50 OR relative standard error >0.3 on at least 1 year's data; thus, no t-test was done.

Data for four tobacco products—hookah, snus, dissolvable tobacco, and electronic cigarettes, were first collected in the NYTS in 2011. During 2011–2012—current use of electronic cigarettes nearly doubled among both middle school (0.6% to 1.1%) and high school (1.5% to 2.8%) students, and hookah use increased among high school students (4.1% to 5.4%). During the same period, significant decreases occurred in current use of bidis and kreteks among both middle and high school students, as well as in dissolvable tobacco use among high school students. A substantial proportion of youth tobacco use occurs with products other than cigarettes, so monitoring and prevention of youth tobacco use needs to incorporate other products, including those that are new or emerging.

#### Electronic Cigarettes

During 2011–2012, data from the NYTS suggested a doubling of electronic cigarette use among U.S. middle and high school students. Among all students in grades 6–12, ever use of electronic cigarettes increased from 3.3% to 6.8% (Tables 13.17–13.18); current electronic cigarette use increased from 1.1% to 2.1%, and current use of both electronic-cigarettes and conventional cigarettes increased from 0.8% to 1.6%. In 2012, among ever electronic cigarette users, 9.3% reported never smoking conventional cigarettes; among current electronic cigarette users, 76.3% reported current conventional cigarette smoking.

Among middle school students, ever electronic cigarette use increased from 1.4% to 2.7% during 2011–2012 (Tables 13.17–13.18); current electronic cigarette use increased from 0.6% to 1.1% (p <0.05), and current use of both electronic cigarettes and conventional cigarettes increased from 0.3% to 0.7%. In 2012, among middle school ever electronic cigarette users, 20.3% reported never smoking conventional cigarettes; among middle school current electronic cigarette users, 61.1% reported current conventional cigarette smoking.

Among high school students, ever electronic cigarette use increased from 4.7% to 10.0% during 2011–2012 (Tables 13.17–13.18); current electronic cigarette use increased from 1.5% to 2.8%, and current use of both electronic cigarettes and conventional cigarettes increased from 1.2% to 2.2%. In 2012, among high school ever electronic cigarette users, 7.2% reported never smoking conventional cigarettes; among high school current electronic cigarette users, 80.5% reported current conventional cigarette smoking. Patterns of use by race/ethnicity are shown in Table 13.18.

#### Current Prevalence Among Adults

Given the range of tobacco products currently being used by adults, including new and emerging tobacco products that have been heavily marketed, definitions of overall current tobacco use for adults should incorporate a range of products. NSDUH provides data on several tobacco products in addition to cigarettes, including smokeless tobacco, cigars, and pipe tobacco (Table 13.19). Data from the 2012 NSDUH show that the prevalence of combustible (cigarettes, cigar, or pipe tobacco) tobacco product use among adults 18 years of age or older was 25.2% and the prevalence of overall tobacco product use (cigarettes, cigars, pipe tobacco, and smokeless) was 27.3%, both of which were significantly higher than the 22.0% prevalence of cigarette smoking (Table 13.19). In addition, NSDUH data suggest that declines in cigarette smoking may be masking persistently high cigarette initiation rates (Figure 13.26). Overall, 2.3 million persons 12 years of age or older initiated cigarette use in 2012, a level equivalent to that observed in 2005. These data on persistently high cigarette initiation rates are not inconsistent with data shown in Table 13.2; however, data in Figure 13.26 focus on somewhat different and more recent aspects of the problem. Table 13.2 shows the age of smoking initiation among adults 30–39 years of age who had ever smoked daily. Figure 13.26 shows the recent patterns of ever smoking even a single cigarette. The proportion of adults (18 years of age or older) who initiated cigarette use in the previous year was greater than prior years. If this pattern continues and is also reflected in those who ever become daily smokers by 30 years of age, the high rates of initiation below 18 years of age shown in Table 13.2 could improve in the future.

Table 13.19 Percentage of tobacco product use in the past month among persons 18 years of age and older, 2002–2012

Substance | 2002 | 2003 | 2004 | 2005 | 2006 | 2007 | 2008 | 2009 | 2010 | 2011 | 2012
Total tobacco products^a^ | 30.8^b^ | 30.2^b^ | 29.6^b^ | 29.9^b^ | 30.1^b^ | 29.2^b^ | 28.8^b^ | 28.1 | 27.8 | 26.9 | 27.3
Cigarettes^c^ | 25.8^b^ | 25.2^b^ | 24.7^b^ | 24.7^b^ | 24.8^b^ | 24.1^b^ | 23.7^b^ | 23.0^d^ | 22.6 | 21.7 | 22.0
Smokeless tobacco | 3.5 | 3.4 | 3.1^b^ | 3.3 | 3.5 | 3.3 | 3.6 | 3.5 | 3.6 | 3.3 | 3.6
Cigars | 5.5 | 5.5 | 5.8 | 5.8 | 5.7 | 5.5 | 5.5 | 5.4 | 5.4 | 5.2 | 5.4
Pipe tobacco | 0.8 | 0.7^b^ | 0.8^d^ | 0.9 | 1.0 | 0.8 | 0.8^d^ | 0.8 | 0.9 | 0.8 | 1.0
Cigarettes^c^ or cigars | 28.5^b^ | 27.9^b^ | 27.6^b^ | 27.7^b^ | 27.7^b^ | 27.0^b^ | 26.4^b^ | 25.8^d^ | 25.5 | 24.6 | 24.8
Cigarettes,^c^ cigars, or pipe tobacco | 28.8^b^ | 28.2^b^ | 27.9^b^ | 28.0^b^ | 28.0^b^ | 27.3^b^ | 26.7^b^ | 26.1 | 25.8 | 24.9 | 25.2

Source: Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality, National Survey on Drug Use and Health, 2002–2012.

a Tobacco products include cigarettes, smokeless tobacco (i.e., chewing tobacco or snuff), cigars, or pipe tobacco.

b The difference between estimate and 2012 estimate is statistically significant at the 0.01 level.

c Past-month cigarette use is defined as smoking during the 30 days preceding the survey and smoking 100 cigarettes or more in a lifetime. Respondents with an unknown lifetime number of cigarettes smoked were excluded from the analysis.

d The difference between this estimate and 2012 estimate is statistically significant at the 0.05 level.

Figure 13.26 Cigarette initiation during the past year among persons 12 years of age and older, by age at first use, 2002–2012

Source: Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality, National Survey on Drug Use and Health, 2002–2012.

^a^ Difference between this estimate and the 2012 estimate is statistically significant at the .05 level.

Stacked bar chart shows that from 2002 to 2012 annual cigarette initiation rates among those 12 years of age and older peaked at 2.5 million persons in 2006. Despite a decrease to 2.2 million persons in 2007, rates remained at 2.5 million persons in 2008 and 2009 before decreasing slightly to 2.3 million persons in 2012. Each year, rates of cigarette initiation were higher among those younger than 18 years of age than among those 18 years of age and older.

#### Electronic Cigarettes

Although NSDUH did not measure electronic cigarette use in 2012 and other nationally representative surveillance data on the awareness and use of electronic cigarettes remains limited, all available data show rapid increases in recent years. Data from the HealthStyles Survey show that awareness of electronic cigarettes among adults 18 years of age or older increased from 40.9% in 2010 to 57.9% in 2011 (King et al. 2013). Ever use of electronic cigarettes also nearly doubled among all adults during 2010–2011, from 3.3% to 6.2% (Table 13.20). During the same period, the prevalence of ever electronic cigarette use among current cigarette smokers increased from 9.8% to 21.2%, while the prevalence among former cigarette smokers increased from 2.5% to 7.4%. Prevalence remained unchanged among never cigarette smokers (1.3%). Other studies described in Table 13.20 are consistent with these results.

Table 13.20 Sources of data and prevalence of electronic nicotine delivery systems (ENDS); United States, 2012–2013

Study | Study design/population | Findings
McMillen et al. 2012 | - Social Climate Survey of Tobacco Control; - 3,240 online surveys and telephone interviews; - 2010; - United States | Ever use of ENDS (%); - Overall: 1.8; - Smoking status:; – Never: 0.3; – Former: 1.5; – Nondaily: 8.2; – Daily: 6.2; - Region:^a^; – Northeast: 2.7; – Midwest: 1.4; – South: 1.6; – West: 1.9; - Race:; – White: 1.7; – Black: 1.9; – Other: 1.8; - Years of age:; – 18–24: 2.5; – ≥25: 1.6; - Education:; – <High school diploma: 0.7; – High school diploma: 1.7; – Some college: 3.7; – College degree: 0.5
Pearson et al. 2012 | - Legacy Longitudinal Smoker Cohort (LLSC) (n = 3658); - Knowledge Networks' KnowledgePanel (n=2,649); - 2010 online surveys and telephone interviews; - United States | Prevalence of ENDS use among Knowledge Networks' KnowledgePanel; - Ever use of ENDS:; – Never smoker: 0.8% (0.4–1.7); – Former smoker: 2.0% (1.0–3.8); – Current smoker: 11.4% (9.3–14.0); - Use for current smokers, % (95% CI):; – Overall: 11.4 (9.2–14.0); – Gender:; ○ Male: 12.6 (9.2–16.9); ○ Female: 10.3 (7.7–13.7); – Race/ethnicity:; ○ White: 11.8 (9.4–14.7); ○ Black: 8.2 (3.6–17.7); ○ Hispanic: 10.2 (5.1–19.6); ○ Other: 18.1 (8.4–34.6); – Education:; ○ <High school diploma: 11.6 (6.5–19.8); ○ High school diploma or GED: 8.5 (6.0–11.9); ○ Some college: 13.6 (9.8–18.5); ○ College degree: 13.7 (8.4–21.6); Prevalence of ENDS use among LLSC; - Ever use of ENDS:; – Never smoker: Not reported; – Former smoker: 3.1% (1.3–7.1); – Current smoker: 6.4% (5.3–7.7); - Use for current smokers, % (95% CI):; – Overall: 6.4 (5.3–7.7); – Gender:; ○ Male: 7.3 (5.6–9.5); ○ Female: 5.3 (4.2–6.7); – Race/ethnicity:; ○ White: 7.4 (6.1–9.1); ○ Black: 0.8 (0.3–2.0); ○ Hispanic: 5.5 (3.2–9.5); ○ Other: 6.0 (2.5–13.6); – Education:; ○ <High school diploma: 3.4 (2.0–7.7); ○ High school diploma or GED: 7.0 (5.3–9.1); ○ Some college: 7.4 (5.2–10.4); ○ College degree: 9.4 (5.6–15.5)
Adkison et al. 2013 | - Wave 8 of the International Tobacco Control Four-Country Survey:; – Canada: n = 1,581; – United States: n = 1,520; – UK: n = 1,325; – Australia: n = 1,513; - July 2010–June 2011; - Online surveys and telephone interviews | - Current ENDS user, United States: 1.08% (95% CI, 0.52–2.12)
King et al. 2013 | - HealthStyles Survey; - 4,184 adults (≥18 years of age); - 2010 mail survey; - United States | Ever use of ENDS^b^, % (95% CI); - Gender:; – Male: 2.3 (1.3–3.4); – Female: 1.9 (1.3–2.6); - Years of age:; – 18–24: —^c^; – 25–34: 2.9 (1.1–4.7); – 35–44: 3.4 (2.0–4.8); – 45–54: 1.9 (1.0–2.8); – 55–64: 2.2 (0.9–3.4); – ≥65: 0.8 (0.2–1.4); - Race/ethnicity:; – White, non-Hispanic: 2.4 (1.6–3.2); – Black, non-Hispanic: —^c^; – Other, non-Hispanic: 1.8 (0.4–3.2); – Hispanic: 2.3 (0.9–3.7); - Education:; – <High school: —^c^; – High school graduate: 3.1 (1.3–5.0); – Some college: 2.3 (1.4–3.2); – College graduate: 1.5 (0.7–2.2); - Annual household income:; – <$15,000: 1.1 (0.3–1.9); – $15,000–$24,999: 1.6 (0.4–2.9); – $25,000–$39,999: 2.9 (0.6–5.2); – $40,000–$59,999: 1.9 (0.7–3.1); – ≥$60,000: 2.4 (1.5–3.3); - Region:^a^; – Northeast: 1.1 (0.3–1.9); – Midwest: 3.3 (1.5–5.1); – South: 1.4 (0.8–2.0); – West: 3.0 (1.7–4.2); - Smoking status:; – Current smoker: 6.8 (4.6–8.9); – Former smoker: 0.6 (0.2–1.1); – Never smoker: 1.2 (1.5–2.7); - Total: 2.1 (1.5–2.7)
King et al. 2013 | - HealthStyles Survey; - 2,505 adults (≥18 years of age); - 2010 Web survey; - United States | Ever use of ENDS^b^, % (95% CI); - Gender:; – Male: 3.0 (1.9–4.2); – Female: 3.7 (2.4–4.9); - Years of age:; – 18–24: 7.0 (3.0–10.9); – 25–34: 3.1 (1.4–4.8); – 35–44: 3.2 (1.4–5.0); – 45–54: 3.2 (1.3–5.2); – 55–64: 2.9 (1.1–4.8); – ≥65: —^c^; - Race/ethnicity:; – White, non-Hispanic: 3.8 (2.7–4.9); – Black, non-Hispanic: —^c^; – Other, non-Hispanic: —^c^; – Hispanic: 3.0 (1.0–5.1); - Education:; – <High school: 4.3 (1.7–6.9); – High school graduate: 4.0 (2.2–5.7); – Some college: 3.6 (2.0–5.1); – College graduate: 2.0 (0.8–3.2); - Annual household income:; – <$15,000: 3.5 (1.5–5.6); – $15,000–$24,999: —^c^; – $25,000–$39,999: 3.5 (1.3–5.8); – $40,000–$59,999: 2.5 (1.1–3.8); – ≥$60,000: 3.5 (2.1–4.9); - Region:^a^; – Northeast: —^c^; – Midwest: 5.4 (3.1–7.6); – South: 2.5 (1.4–3.6); – West: 3.7 (2.0–5.5); - Smoking status:; – Current smoker: 9.8 (6.9–12.6); – Former smoker: 2.5 (0.8–4.2); – Never smoker: 1.3 (0.5–2.0); - Total: 3.3 (2.5–4.2)
King et al. 2013 | - HealthStyles Survey; - 4,050 adults (≥18 years of age); - 2011 Web survey; - United States | Ever use of ENDS^b^, % (95% CI); - Gender:; – Male: 5.8 (4.4–7.2); – Female: 6.6 (5.1–8.2); - Years of age:; – 18–24: 8.1 (4.0–12.2); – 25–34: 6.6 (3.9–9.3); – 35–44: 5.7 (3.6–7.7); – 45–54: 8.0 (5.5–10.5); – 55–64: 5.5 (3.4–7.5); – ≥65: 3.7 (1.9–5.4); - Race/ethnicity:; – White, non-Hispanic: 6.8 (5.6–8.1); – Black, non-Hispanic: 4.5 (1.6–7.3); – Other, non-Hispanic: 6.1 (1.8–10.4); – Hispanic: 3.9 (1.1–6.7); - Education:; – <High school: 7.4 (3.4–11.4); – High school graduate: 7.5 (5.4–9.7); – Some college: 6.1 (4.6–7.7); – College graduate: 4.4 (2.9–5.9); - Annual household income:; – <$15,000: 7.5 (4.3–10.7); – $15,000–$24,999: 5.7 (1.9–9.4); – $25,000–$39,999: 9.4 (5.7–13.0); – $40,000–$59,999: 4.9 (2.9–6.9); – ≥$60,000: 5.6 (4.3–7.0); - Region:^a^; – Northeast: 5.6 (3.5–7.7); – Midwest: 7.7 (5.3–10.1); – South: 6.2 (4.4–8.0); – West: 5.3 (3.3–7.3); - Smoking status:; – Current smoker: 21.2 (17.0–25.4); – Former smoker: 7.4 (5.0–9.7); – Never smoker: 1.3 (0.7–1.8); - Total: 6.2 (5.2–7.3)
Regan et al. 2013 | - ConsumerStyles Survey; - 2009: n = 21,240; - 2010: n = 20,000; - United States | Ever use ENDs (n = 249): % (95% CI)^d^; - Gender:; – Male: 6.5 (4.9–8.0); – Female: 10.5 (7.9–13.2); - Years of age:; – 18–24: 10.1 (3.1–17.0); – 25–34: 9.2 (6.2–12.2); – 35–44: 6.9 (4.9–9.0); – 45–54: 9.2 (7.1–11.3); – 55–64: 5.9 (3.4–8.4); – ≥65: 7.9 (4.8–11.1); - Race/ethnicity:; – White, non-Hispanic: 8.3 (6.4–10.1); – Black, non-Hispanic: 8.9 (4.9–12.9); – Other, non-Hispanic: 8.2 (4.6–11.7); – Hispanic: 8.9 (4.5–13.3); - Education:; – <High school: 17.8 (5.4–30.2); – High school graduate: 9.5 (6.2–12.7); – Some college: 8.0 (5.9–10.1); – ≥College graduate: 7.0 (4.3–9.6); - Annual household income:; – <$15,000: 12.9 (5.8–20.0); – $15,000–$24,999: 12.6 (6.7–18.5); – $25,000–$39,999: 8.1 (4.7–11.4); – $40,000–$59,999: 9.3 (5.1–13.5); – ≥$60,000: 6.0 (4.7–7.4); - Region:; – Northeast: 9.5 (4.9–14.2); – Midwest: 8.6 (5.5–11.8); – South: 8.1 (6.0–10.3); – West: 7.3 (5.1–9.6); - Smoking status:; – Current smoker: 18.2 (13.8–22.7); – Former smoker: 6.2 (4.0–8.3); – Never smoker: 3.8 (2.7–4.9); - Tobacco use:; – Uses tobacco: 17.2 (13.6–20.8); – Uses one tobacco product: 14.7 (10.6–18.7); – Uses >1 tobacco product: 21.1 (14.3–28.0); – Does not use tobacco: 3.6 (2.6–4.6)
Regan et al. 2013 | - ConsumerStyles Survey; - 2009: n = 21,240; - 2010: n = 20,000; - United States | Ever use ENDs (n = 249): OR (95% CI)^d^; - Gender; – Male: 0.59 (0.40–0.86)^*^; – Female: 1; - Years of age:; – 18–24: 1.30 (0.54–3.14); – 25–34: 1.17 (0.67–2.05); – 35–44: 0.87 (0.51–1.48); – 45–54: 1.18 (0.71–1.93); – 55–64: 0.73 (0.39–1.36); – ≥65: 1; - Race/ethnicity:; – White, non-Hispanic: 1; – Black, non-Hispanic: 1.08 (0.62–1.89); – Other, non-Hispanic: 0.99 (0.58–1.68); – Hispanic: 1.09 (0.60–1.97); - Education:; – <High school: 2.90 (1.13–7.45)^*^; – High school graduate: 1.41 (0.81–2.45); – Some college: 1.17 (0.71–1.92); – ≥College graduate: 1; - Annual household income:; – <$15,000: 2.24 (1.25–4.02) *; – $15,000–$24,999: 1.36 (0.82–2.28); – $25,000–$39,999: 1.59 (0.92–2.77); – $40,000–$59,999: 2.30 (1.17–4.51)^*^; – ≥$60,000: 1; - Region:; – Northeast: 1.33 (0.71–2.51); – Midwest: 1.19 (0.71–2.01); – South: 1.11 (0.72–1.72); – West: 1; - Smoking status:; – Current smoker: 5.71 (3.72–8.76) *; – Former smoker: 1.68 (1.03–2.72) *; – Never smoker: 1; - Tobacco use:; – Uses tobacco: 5.55 (3.80–8.11) *; – Uses one tobacco product: 4.59 (3.00–7.04) *; – Uses >1 tobacco product: 7.17 (4.36–11.78) *; – Does not use tobacco: 1
Regan et al. 2013 | - ConsumerStyles Survey; - 2009: n = 21,240; - 2010: n = 20,000; - United States | Past month use of ENDS (n = 115): % (95% CI)^d^; - Gender:; – Male: 3.6 (2.4–4.9); – Female: 3.5 (2.5–4.6); - Years of age:; – 18–24: —^e^; – 25–34: 3.7 (1.6–5.7); – 35–44: 2.9 (1.7–4.1); – 45–54: 4.8 (3.2–6.4); – 55–64: 3.1 (1.2–5.0); – ≥65: 5.2 (2.5–7.9); - Race/ethnicity:; – White, non-Hispanic: 3.3 (2.3–4.3); – Black, non-Hispanic: 5.8 (2.4–9.3); – Other, non-Hispanic: 3.1 (1.1–5.2); – Hispanic: 4.3 (0.9–7.8); - Education:; – <High school: —^e^; – High school graduate: 4.1 (1.9–6.3); – Some college: 3.4 (2.2–4.5); – ≥College graduate: 2.9 (1.8–4.1); - Annual household income:; – <$15,000: 4.6 (1.7–7.5); – $15,000–$24,999: 4.1 (1.6–6.6); – $25,000–$39,999: 4.3 (1.9–6.8); – $40,000–$59,999: 3.7 (1.3–6.1); – ≥$60,000: 3.0 (1.9–4.0); - Region:; – Northeast: 4.2 (1.7–6.6); – Midwest: 2.8 (1.2–4.4); – South: 3.5 (2.3–4.8); – West: 4.2 (2.5–6.0); - Smoking status:; – Current smoker: 6.3 (4.1–8.6); – Former smoker: 2.9 (1.4–4.5); – Never smoker: 2.2 (1.3–3.1); - Tobacco use:; – Uses tobacco: 7.1 (5.0–9.1); – Uses one tobacco product: 4.3 (2.6–6.0); – Uses >1 tobacco product: 11.4 (6.9–15.9); – Does not use tobacco: 1.8 (1.1–2.5)
Regan et al. 2013 | - ConsumerStyles Survey; - 2009: n = 21,240; - 2010: n = 20,000; - United States | Past month use of ENDS (n = 115): OR (95% CI)^d^; - Gender:; – Male: 1.03 (0.64–1.67); – Female: 1; - Years of age:; – 18–24: 0.46 (0.12–1.74); – 25–34: 0.69 (0.31–1.53); – 35–44: 0.54 (0.27–1.10); – 45–54: 0.91 (0.47–1.74); – 55–64: 0.59 (0.25–1.35); – ≥65: 1; - Race/ethnicity:; – White, non-Hispanic: 1; – Black, non-Hispanic: 1.79 (0.89–3.61); – Other, non-Hispanic: 0.94 (0.45–1.99); – Hispanic: 1.32 (0.55–3.19); - Education:; – <High school: 3.47 (1.15–10.46)^e^; – High school graduate: 1.42 (0.70–2.85); – Some college: 1.15 (0.67–1.99); – ≥College graduate: 1; - Annual household income:; – <$15,000: 1.40 (0.68–2.89); – $15,000–$24,999: 1.48 (0.74–2.97); – $25,000–$39,999: 1.25 (0.58–2.69); – $40,000–$59,999: 1.57 (0.73–3.35); – ≥$60,000: 1; - Region:; – Northeast: 0.98 (0.46–2.09); – Midwest: 0.65 (0.31–1.35); – South: 0.83 (0.47–1.47); – West: 1; - Smoking status:; – Current smoker: 3.06 (1.72–5.42)^e^; – Former smoker: 1.36 (0.68–2.73); – Never smoker: 1; - Tobacco use:; – Uses tobacco: 4.21 (2.53–7.01)^e^; – Uses one tobacco product: 2.48 (1.40–4.40)^e^; – Uses >1 tobacco product: 7.10 (3.89–12.98)^e^; – Does not use tobacco: 1

Note: GED = general education development; OR = odds ratio; CI = confdence interval.

a Regions are taken from U.S. Census Bureau: Northeast (Connecticut, Maine, Massachusetts, New Hampshire, New Jersey, New York, Pennsylvania, Rhode Island, and Vermont); Midwest (Indiana, Illinois, Iowa, Kansas, Michigan, Minnesota, Missouri, Nebraska, North Dakota, Ohio, South Dakota, and Wisconsin); South (Alabama, Arkansas, Delaware, District of Columbia, Florida, Georgia, Kentucky, Louisiana, Maryland, Mississippi, North Carolina, Oklahoma, South Carolina, Tennessee, Texas, Virginia, and West Virginia); West (Alaska, Arizona, California, Colorado, Hawaii, Idaho, New Mexico, Montana, Oregon, Nevada, Utah, Washington, and Wyoming).

b Defined as a response of “electronic cigarettes or e-cigarettes” to the question, “Have you tried any of the following products, even just one time?”

c Relative standard error ≥40%.

d Among those who had heard of ENDS.

e Unreliable estimate; data censored because relative standard error >45%.

* Significant at p <0.05.

## Conclusions

Extensive national surveys document the rise and subsequent decline of cigarette use, the current heterogeneity of cigarette use across subgroups of the population, and the changing patterns of tobacco product use. Such data are requisite for continually evaluating and reshaping tobacco control strategies. The data reviewed support the following conclusions:

In the United States, the prevalence of current cigarette smoking among adults has declined from 42% in 1965 to 18% in 2012.

1. The prevalence of current cigarette smoking declined first among men (between 1965 and the 1990s), and then among women (since the 1980s). However, declines in the prevalence of smoking among adults (18 years of age and older) have slowed in recent years.
2. Most first use of cigarettes occurs by 18 years of age (87%), with nearly all first use by 26 years of age (98%).
3. Very large disparities in tobacco use remain across racial/ethnic groups and between groups defined by educational level, socioeconomic status, and region.
4. In the United States, there are now more former smokers than there are current smokers. More than half of all ever smokers have quit smoking.
5. The rate of quitting smoking among recent birth cohorts has been increasing, and interest in quitting is high across all segments of society.
6. Patterns of tobacco use are changing, with more intermittent use of cigarettes and an increase in use of other products.

## Summary and Implications

Cigarette smoking among both youth and adults has declined since 1964. However, declines in the prevalence of cigarette smoking among adults have slowed in recent years. Survey data indicate that tobacco control efforts need to not only address the population generally but also to focus on subpopulations with a higher prevalence of tobacco use and lower rates of quitting. Some of the highest prevalence rates have been observed among persons of lower socioeconomic status, sexual minorities (including individuals who are gay, lesbian, bisexual and transgender, and individuals with same-sex relationships and/or attraction), high school dropouts (Fagan et al. 2007; Lee et al. 2009; Garrett et al. 2011, 2013; SAMSHA 2013) and in Appalachia and the South (Pickle and Su 2002) as well as among vulnerable populations with complex comorbid medical illness (e.g. HIV/AIDS and cardiovascular disease) (Crothers et al. 2009; Hoffman et al. 2009; Marshall et al. 2009; Vidrine 2009; Levine et al. 2010; Tesoriero et al. 2010; Pines et al. 2011; Rahmanian et al. 2011), mental illness, and alcohol and substance abuse disorders (CDC 2013; Prochaska et al. 2008; Schroeder and Morris 2010; Villanti et al. 2012). Additionally, polytobacco use is now very common, especially among youth and young adults, and a recent upsurge in the use of cigars has also occurred. Limited national surveillance data are available to monitor the use of nonconventional tobacco products, particularly electronic cigarettes and hookah pipes, suggesting the need for sustained and expanded efforts to capture all forms of tobacco use. Given the rapid increase in electronic cigarette use among both adults and adolescents, rigorous surveillance of these products is particularly important, including their impact on the initiation and cessation of conventional tobacco use and concurrent use with other conventional tobacco products. Without question, data collection systems need the capacity to monitor the patterns of both conventional and nonconventional tobacco use across all segments of our society. The tables in this chapter provide the prevalence of use of cigarettes and other tobacco products stratified by gender, race/ethnicity, education, age groups, poverty status, and region of the United States; however, the high prevalence of smoking in some other segments of society suggests the need for national data collection systems which have the capacity to provide surveillance of tobacco use patterns in other segments of society where higher prevalence of tobacco use has been observed.

## Appendix 13.1 Sources of Data

Data in this chapter were obtained from three national surveys: National Health Interview Survey (NHIS), National Survey on Drug Use and Health (NSDUH), and the Youth Risk Behavior Survey (YRBS) (Table 13.1).

### National Health Interview Survey

NHIS is a multipurpose survey conducted by the National Center for Health Statistics (NCHS) of the Centers for Disease Control and Prevention (CDC) and is the principal source of information on the health of the civilian, noninstitutionalized population of the United States. The NHIS has been conducted continuously since 1957. Questions on smoking have been included in selected survey years since 1965, and detailed items allowing classification by race and ethnicity have been included since 1978. Detailed questions on tobacco use are included in a Cancer Control Supplement to the NHIS, which was initiated in 1987 and subsequently conducted in 1992, 2000, 2005, and 2011. Face-to-face interviews are used to collect confidential data from a representative sample of the population at the respondent's place of residence (NCHS 2008).

The sampling plan follows a multistage area probability design that permits the representative sampling of households and noninstitutional group quarters (e.g., college dormitories) in all 50 states and the District of Columbia. Non-Hispanic African American or Black, Hispanic or Latino, and Asian persons are oversampled. For each family in NHIS, one sample child (younger than 18 years of age) and one sample adult are randomly selected, and information on each is collected. For children and those adults not at home during the interview, information is provided by a knowledgeable adult family member. Since 1974, only self-reports of cigarette smoking and use of other tobacco products have been used, and thus no proxy data have been employed since 1974 on questions of import to this report. Since 1997, NHIS has been conducted using computer-assisted personal interviewing by interviewers from the U.S. Census Bureau; sampling and interviewing are continuous throughout each year (NCHS 2008).

### National Survey on Drug Use and Health

NSDUH is an annual survey of the civilian, noninstitutionalized population 12 years of age and older in the United States. Before 2002, this survey, which has been conducted by the federal government since 1971, was called the National Household Survey on Drug Abuse. NSDUH is the primary source of statistical information on the use of illegal drugs by the U.S. population; face-to-face interviews are used to collect confidential data from a representative sample of the population at the respondent's place of residence. The survey is sponsored by the Substance Abuse and Mental Health Services Administration (SAMHSA) of the U.S. Department of Health and Human Services and is planned and managed by SAMHSA's Center for Behavioral Health Statistics and Quality.

Data are collected using audio computer-assisted self-interviewing, and respondents are given a US$30 incentive payment for participation. The total targeted sample size for 1 year of 67,500 participants is allocated equally across three age groups: 12–17, 18–25, and 26 years of age and older. The NSDUH sampling frame includes residents of noninstitutional group quarters (e.g., shelters, rooming houses, dormitories, and group homes), residents of the 50 states and the District of Columbia, and civilians living on military bases. The sample excludes persons with no fixed household address (e.g., homeless transients not in shelters) and long-term residents of institutional group quarters (e.g., prisons and hospitals).

### Youth Risk Behavior Surveillance System

Developed in 1990 by CDC, the YRBSS monitors priority health risk behaviors, including tobacco use, among high school students in the United States. In addition to the surveys that are conducted by state, local, territorial, and tribal health and education agencies, there is a national YRBS conducted by CDC. The current report includes data from the national YRBS only, which has a sampling frame of all public and private school students in grades 9–12 in the 50 states and the District of Columbia. A three-stage cluster sample design is used to sample (1) large-sized counties or groups of smaller adjacent counties, (2) public and private schools with a probability proportional to the schools' enrollment, and (3) one or two randomly selected classes in each grade. Examples of classes include homerooms, classes of a required discipline (e.g., English or social studies), and all classes meeting during a required period (e.g., second period). All students in a sampled class are eligible to participate. Oversampling is used to achieve sufficiently large subsamples of Black or African American and Hispanic or Latino students to enable separate analyses of these subgroups. Schools that decline to participate in the original sample are not replaced. Students complete self-administered, paper-and-pencil questionnaires and record their answers directly in the questionnaire booklet or on a separate computer-scannable answer sheet (CDC 2013). Local procedures to obtain the permission of parents are followed. Trained personnel administer the questionnaires to students in their classrooms for the national survey and for most state and local surveys. The participation of students is both voluntary and anonymous (CDC 2013).

## Appendix 13.2 Measures of Tobacco Use

### Validity of Measures of Tobacco Use Among Youth

All of the data on tobacco use among youth that are presented in this report are based on retrospective, self-reported responses to questionnaires. Because of the retrospective nature of data collection, and because tobacco use is viewed by many as a socially undesirable behavior, there is a risk of inaccurate or dishonest responses. Because it was not feasible to verify the self-reported data included here, it is important for researchers to interpret these data with some caution and an understanding of possible sources of inaccuracy. Many factors can affect the validity of self-reported data—factors that can be categorized as cognitive or situational. Cognitive processes that affect responses include comprehension of the question, retrieval of relevant information from memory, decision making about the adequacy of the information retrieved, and the generation of a response (Brener et al. 2003). Each of these processes can contribute to errors in responses and, subsequently, to problems with validity.

Situational factors that affect the validity of self-reported data refer to characteristics of the external environment in which the survey is being conducted. These include the setting (i.e., school or home based), the method (i.e., self-administered questionnaire or in-person interview), the social desirability of the behavior being reported, and the perception of privacy and/or confidentiality of responses (U.S. Department of Health and Human Services [USDHHS] 1994; Brener et al. 2003). Many studies have found that youth report a higher number of sensitive behaviors when a survey is completed in a school setting rather than in their homes (Gfroerer et al. 1997; Hedges and Jarvis 1998; Kann et al. 2002). For example, Kann and colleagues (2002) compared the school-based National Youth Risk Behavior Survey (YRBS) with the household-based YRBS supplement to the National Health Interview Survey (NHIS). The study found that the school-based survey produced a significantly higher reporting of many sensitive behaviors, such as driving after drinking alcohol, binge drinking, and currently using marijuana and cocaine. Four measures of various stages of the smoking uptake process were higher in the school-based survey, but estimates of current cigarette use and frequent cigarette use, while elevated in the school-based survey, were not significantly different from estimates generated in the household-based survey. Few differences in nonsensitive behaviors were observed. Two other studies (Gfroerer et al. 1997; Brener et al. 2003) indicate that although self-reported estimates of current use of alcohol and illicit drugs were higher in the school-based versus household-based surveys, estimates of current cigarette smoking were quite similar across settings. All three of these studies used self—rather than interviewer—administered interviews/questionnaires. Nevertheless, the provision of privacy that school surveys provide is important, especially if smoking becomes more socially unacceptable over time. Notably, household-based surveys are more likely to include youth who drop out of school or are frequently absent from school, and these groups are more likely to smoke.

Self-administered methods of data collection have generally produced higher reporting of sensitive behaviors, including tobacco use, than have interviewer-administered methods (Turner et al. 1992; Aquilino 1994; Brittingham et al. 1998). For example, Turner and colleagues (1992) found that the prevalence of current smoking among 12- to 17-year-olds based on reports in the self-administered version of the National Survey on Drug Use and Health (NSDUH) home-based survey was considerably higher (by 10–30%) than it was using the interviewer-administered version. The absence of personal interaction with an interviewer on self-administered surveys may reduce the reporting biases associated with perceived privacy and the social desirability of a behavior (Brener et al. 2003).

Another situational influence is the use of the “bogus pipeline” (Brener et al. 2003). This method has been used to improve the validity of self-reported measures of smoking, especially in school-based surveys. Respondents are told that a biochemical test will be used to accurately evaluate their smoking behavior after the questionnaire is completed, although in fact such a test will not be used. This method has been associated with higher reported smoking prevalence (Aguinis et al. 1993). None of the surveys used in this report make use of the bogus pipeline, but each survey has taken alternative steps to ensure that the survey setting is private and that the data collected are at least confidential if not anonymous.

In conclusion, the factors described above may affect the point estimate of smoking prevalence. However, if these factors remain stable over the years, they should not affect the trends seen over time.

### Validity of Measures of Tobacco Use Among Adults

All of the data on tobacco use among adults that were presented in this report were based on retrospective self-reported responses to questionnaires. Biochemical validation studies suggest that data on self-reported cigarette smoking are generally valid, except in certain situations, such as in conjunction with intense smoking cessation programs and with certain populations, such as pregnant women or adolescents (Velicer et al. 1992; Kendrick et al. 1995; USDHHS 2012). Misclassification may also be more common among intermittent smokers. Additionally, smokers may misreport the number of cigarettes smoked per day because of digit preference (preference for multiples of 10) (Klesges et al. 1995). Regardless, a meta-analysis of 26 validation studies found that self-reported smoking status is generally accurate (Patrick et al. 1994), particularly when interviewer-administered questionnaires are used. It should be noted here that much of the research literature on the validity of self-reported data is restricted to cigarette smoking—cigars and smokeless tobacco are rarely addressed. As such, a discussion of the factors that may affect validity is warranted so that the data presented in the present report are interpreted with some caution and an understanding of possible sources of inaccuracy. Clearly, many factors can affect the validity of self-reported data, such as response biases and methodologic features of surveys.

Methodologic differences in survey administration—including, but not limited to, timing, survey question order, sampling, data collection mode (e.g., computer-assisted personal interviewing vs. computer-assisted telephone interviewing), participation rates, and operational definitions—can affect prevalence estimates of tobacco use (Ryan et al. 2012). NHIS and NSDUH both use computer-assisted personal interviewing, which is done in the home. NSDUH differs from NHIS, however, with respect to the operational definition of cigarette smoking (Delnevo and Bauer 2009). NHIS defines current smoking among adults as smoking at least 100 cigarettes during one's lifetime and smoking every day or on some days. In contrast, NSDUH defines current smoking for youth, young adults, and adults as smoking part or all of a cigarette during the past 30 days. The Substance Abuse and Mental Health Services Administration, which sponsors NSDUH, does not use the 100 cigarettes-in-a-lifetime threshold when making estimates of cigarette smoking prevalence from NSDUH data. This likely contributes to the consistently higher estimates from NSDUH noted throughout this report (see “Measures of Tobacco Use” section below) (Ryan et al. 2012). Tables in this chapter continue the criteria described above for youth and young adults. To facilitate comparisons with NHIS, however, data in selected tables on all adults 18 years of age or older incorporate the 100-cigarette threshold, as noted in the footnotes to the tables. Ryan and colleagues (2012) discuss these differences in the definitions of current smoking and how they could affect smoking estimates, particularly in some subpopulations. However, with the use of a modified NSDUH current smoking definition that incorporated the 100-cigarettes-in-a-lifetime threshold, Ryan and colleagues (2012) observed that a notable number of subpopulation estimates (e.g., 26–34 years of age group, Asians, and Hispanics groups) became comparable between the NSDUH and NHIS surveys for the year 2008.

Ryan and associates (2012) also noted other methodologic differences between the surveys beyond the current smoking definition that may contribute to the consistently higher estimates in NSDUH, including survey mode, setting, context, and incentives. The NSDUH interview mode is strictly in person using computer-assisted personal interviewing that is thought to provide respondents with an enhanced sense of privacy. Although NHIS is interviewer administered, some interviews that cannot be fully conducted in person are completed by telephone. Ryan and coworkers (2012) also note that the context of the survey and question placement could be a factor contributing to higher self-report of smoking in NSDUH. Within the NHIS survey context, smoking may be viewed as one of the most serious health behaviors that respondents are asked about. Within NSDUH, in contrast, the survey content focuses almost entirely on substance-use behaviors, both licit and illicit, and respondents may perceive smoking to be one of the more socially acceptable behaviors they are being asked about. Finally, since 2002, NSDUH began paying respondents a US$30 incentive upon completion of the survey, while NHIS remains uncompensated. Although these factors may affect the point estimates of various tobacco use indicators, if the factors remain stable over the years they should not affect the trends seen over time within a given survey. Still, direct comparisons of point estimates across surveys are not advised because of methodologic differences between them. Instead, readers should consider consistency in patterns across years for the same survey.

### Measures of Tobacco Use

Measures of tobacco use differ slightly among surveys and by the target population. For each tobacco use measure, the definitions used in the various surveys are summarized below.

#### Current Smoking: Youth

YRBS defines current smoking among students as having smoked cigarettes on at least 1 day during the 30 days before the survey. NSDUH asks whether the respondent has smoked “part or all of a cigarette” during the past 30 days to determine current usage.

#### Current Smoking: Adult

For NHIS from 1965–1991, current smokers were defined as respondents who had smoked at least 100 cigarettes and who answered “yes” to the question “Do you smoke cigarettes now?” Beginning in 1992, NHIS assessed whether respondents smoked every day, some days, or not at all. Persons who smoked every day or some days were classified as current smokers. In contrast, NSDUH defines a current cigarette smoker as a person who has smoked all or part of a cigarette during the past 30 days. The 100-cigarettes-in-a-lifetime threshold is not traditionally used by NSDUH in reporting the prevalence of current cigarette smoking. This difference, in part, contributes to the consistently higher estimates from NSDUH data than from other surveys. However, the 100-cigarettes-in-a-lifetime threshold question was collected and used in the present report when giving estimates of prevalence for adults.

#### Intermittent and Daily Smoking

In NSDUH, participants who reported that they had smoked on every day during the past 30 days were classified as daily smokers; those who smoked on 1–29 days were classified as intermittent smokers. In NHIS, intermittent smokers were those who report currently smoking “some days,” while daily smokers were those who report currently smoking “every day.”

#### Attempts to Quit Smoking

An attempt to quit smoking was defined in this chapter as having quit smoking for more than 1 day during the previous year. Depending on the year of the survey, NHIS asked about attempts to quit during the past year or in a lifetime. Examples of questions were “During the past 12 months, have you quit smoking for one day or longer?” and “Have you ever stopped smoking for one day or longer?” In the 1998 NHIS, the question was revised to “During the past 12 months, have you stopped smoking for more than one day because you were trying to quit smoking?”

#### Current Use of Smokeless Tobacco

NSDUH defines current use of smokeless tobacco as having used it during the 30 days before the survey. To determine current usage, NSDUH asks whether the respondent has “used snuff, even once” and/or “used chewing tobacco, even once” during the past 30 days. An affirmative answer to either question categorizes that respondent as a current user. YRBS defines current use of smokeless tobacco as using chewing tobacco, snuff, or dip on at least 1 day during the 30 days before the survey. NHIS defines current use of smokeless tobacco as use on every day or some days.

#### Current Cigar Use

NSDUH defines current cigar use as having smoked cigars during the 30 days before the survey. Cigars are defined as “big cigars, cigarillos, and even little cigars that look like cigarettes.” To determine current usage, NSDUH asks whether the respondent has smoked “part or all of a cigar” during the past 30 days. An affirmative answer to either question categorizes that respondent as a current user. NHIS first asks “Have you ever used a cigar?” Those providing an affirmative response are asked “Do you currently smoke cigars every day, some days or not at all?” Those responding “every day” or “some days” are defined as current cigar smokers. YRBS defines current cigar use as smoking cigars, cigarillos, or little cigars on at least 1 day during the 30 days before the survey.

## References

Adkison SE, O'Connor RJ, Bansal-Travers M, Hyland A, Borland R, Yong HH, Cummings KM, McNeill A, Thrasher JF, Hammond D, et al. Electronic nicotine delivery systems: international tobacco control four-country survey. American Journal of Preventive Medicine. 2013;44(3):207-15. [pmid: 23415116].
Aguinis H, Pierce CA, Quigley BM. Conditions under which a bogus pipeline procedure enhances the validity of self-reported cigarette smoking: a meta-analytic review. Journal of Applied Social Psychology. 1993;23(5):352-73.
Anderson CM, Burns DM, Dodd KW, Feuer EJ. Chapter 2: Birth-cohort-specific estimates of smoking behaviors for the U.S. population. Risk Analysis. 2012;32(Suppl 1):S14-S24. [pmid: 22882884].
Aquilino WS. Interview mode effects in surveys of drug and alcohol use: a field experiment. Public Opinion Quarterly. 1994;58(2):210-40.
Backinger CL, Fagan P, O'Connell ME, Grana R, Lawrence D, Bishop JA, Gibson JT. Use of other tobacco products among U.S. adult cigarette smokers: prevalence, trends and correlates. Addictive Behaviors. 2008;33(3):472-89. [pmid: 18053653].
Baker F, Ainsworth SR, Dye JT, Crammer C, Thun MJ, Hoffmann D, Repace JL, Henningfield JE, Slade J, Pinney J, et al. Health risks associated with cigar smoking. JAMA: the Journal of the American Medical Association. 2000;284(6):735-40.
Bhattacharyya N. Trends in the use of smokeless tobacco in United States, 2000–2010. Laryngoscope. 2012;122(10):2175-8. [pmid: 22777912].
Biener L, Albers AB. Young adults: vulnerable new targets of tobacco marketing. American Journal of Public Health. 2004;94(2):326-30. [pmid: 14759950].
Brener ND, Billy JO, Grady WR. Assessment of factors affecting the validity of self-reported health-risk behavior among adolescents: evidence from the scientific literature. Journal of Adolescent Health. 2003;33(6):436-57. [pmid: 14642706].
Brittingham A, Tourangeau R, Kay W. Reports of smoking in a national survey: data from screening and detailed interviews, and from self- and interviewer-administered questions. Annals of Epidemiology. 1998;8(6):393-401. [pmid: 9708875].
Centers for Disease Control. Smokeless tobacco use in rural Alaska. Morbidity and Mortality Weekly Report. 1987;36(10):140-3. [pmid: 3102918].
Centers for Disease Control and Prevention. Cigar smoking among teenagers—United States, Massachusetts, and New York, 1996. Morbidity and Mortality Weekly Report. 1997;46(20):433-40. [pmid: 9182204].
Centers for Disease Control and Prevention. Cigarette use among high school students—United States, 1991–2009. Morbidity and Mortality Weekly Report. 2010;59(26):797-801. [pmid: 20613702].
Centers for Disease Control and Prevention. Methodology of the Youth Risk Behavior Surveillance System—2013. Morbidity and Mortality Weekly Report Recommendations and Reports. 2013;62(RR-1):1-20.
Centers for Disease Control and Prevention. Vital signs: current cigarette smoking among adults aged ≥18 years with mental illness—United States, 2009–2011. Morbidity and Mortality Weekly Report. 2013;62:81-7. [pmid: 23388551].
Crothers K, Goulet JL, Rodriguez-Barradas MC, Gibert CL, Oursler KA, Goetz MB, Crystal S, Leaf DA, Butt AA, Braithwaite RS, et al. Impact of cigarette smoking on mortality in HIV-positive and HIV-negative veterans. AIDS Education and Prevention. 2009;21(3 Suppl):40-53. [pmid: 19537953].
Delnevo CD, Bauer UE. Monitoring the tobacco use epidemic III: The host: data sources and methodological challenges. Preventive Medicine. 2009;48(1 Suppl):S16-S23. [pmid: 18851990].
Delnevo CD, Hrywna M, Foulds J, Steinberg MB. Cigar use before and after a cigarette excise tax increase in New Jersey. Addictive Behaviors. 2004;29(9):1799-807. [pmid: 15530722].
Delnevo CD, Hrywna M. “A whole ‘nother smoke” or a cigarette in disguise: how RJ Reynolds reframed the image of little cigars. American Journal of Public Health. 2007;97(8):1368-75. [pmid: 17600253].
Delnevo CD, Pevzner ES, Steinberg MB, Warren CW, Slade J. Cigar use in New Jersey among adolescents and adults. American Journal of Public Health. 2002;92(6):943-5. [pmid: 12036785].
Delnevo CD, Wackowski OA, Giovenco DP, Manderski MT, Hrywna M, Ling PM. Examining market trends in the United States smokeless tobacco use: 2005–2011. Tobacco Control. 2012. e-print. [doi: 10.1136/tobaccocontrol-2012-050739].
Delnevo CD. Smokers choice: what explains the steady rise of cigar use in the U.S.?. Public Health Reports. 2006;121(2):116-9. [pmid: 16528942].
Excise Tax Reduction Act of 1965. Public Law 89-44. U.S. Statutes at Large. 1966:135. codified at U.S. Code 26, § 5702(a).
Fagan P, Moolchan ET, Lawrence D, Fernander A, Ponder PK. Identifying health disparities across the tobacco continuum. Addiction. 2007;102(Suppl 2):5-29. [pmid: 17850611].
Federal Trade Commission. Federal Trade Commission Cigarette Report for 2009 and 2010. Washington. Federal Trade Commission. 2012. <http://www.ftc.gov/os/2012/09/120921cigarettereport.pdf>. April 17, 2013.
Garrett BE, Dube SR, Trosclair A, Caraballo RS, Pechacek TF, Centers for Disease Control and Prevention. Cigarette smoking—United States, 1965–2008. Morbidity and Mortality Weekly Report: Surveillance Summaries. 2011;60(Suppl):109-13. [pmid: 21430635].
Garrett BE, Dube SR, Winder C, Caraballo RS, National Center for Chronic Disease Prevention and Health Promotion, CDC. Cigarette Smoking—United States, 2006–2008 and 2009–2010. Morbidity and Mortality Weekly Report: Surveillance Summaries. 2013;62(SU-3):81-4. [pmid: 24264495].
Gfroerer J, Wright D, Kopstein A. Prevalence of youth substance use: the impact of methodological differences between two national surveys. Drug and Alcohol Dependence. 1997;47(1):19-30. [pmid: 9279494].
Gilpin EA, Pierce JP. Patterns of cigar use in California in 1999. American Journal of Preventive Medicine. 2001;21(4):325-8. [pmid: 11701305].
Giovino GA. Epidemiology of tobacco use in the United States. Oncogene. 2002;21(48):7326-40. [pmid: 12379876].
Hedges B, Jarvis M. Cigarette smoking. Prescott-Clark P, Primatesta P, editors. Health Survey for England: The Health of Young People, ‘95–97. London. The Stationery Office. 1998:191-221.
Hoffman AC, Starks VL, Gritz ER. The impact of cigarette smoking on HIV/AIDS: urgent need for research and cessation treatment. AIDS Education and Prevention. 2009;21(3 Suppl):1-2. [pmid: 19537949].
Holford TR, Levy DT, McKay LA, Clarke L, Racine B, Meza R, Land S, Jeon J, Feurer EJ. Birth cohort-specific smoking histories: initiation, cessation, intensity, and prevalence patterns for the United States, 1965–2009. American Journal of Preventive Medicine. in press.
Kann L, Brener ND, Warren CW, Collins JL, Giovino GA. An assessment of the effect of data collection setting on the prevalence of health risk behaviors among adolescents. Journal of Adolescent Health. 2002;31(4):327-35. [pmid: 12359378].
Kaplan SD, Lanier AP, Merritt RK, Siegel PZ. Prevalence of tobacco use among Alaska Natives: a review. Preventive Medicine. 1997;26(4):460-5. [pmid: 9245667].
Katz SK, Lavack AM. Tobacco related bar promotions: insights from tobacco industry documents. Tobacco Control. 2002;11(Suppl 1):I92-I101. [pmid: 11893819].
Kendrick JS, Zahniser SC, Miller N, Salas N, Stine J, Gargiullo PM, Floyd RL, Spierto FW, Sexton M, Metzger RW, et al. Integrating smoking cessation into routine public prenatal care: the Smoking Cessation in Pregnancy project. American Journal of Public Health. 1995;85(2):217-22. [pmid: 7856781].
King BA, Alam S, Promoff G, Arrazola R, Dube SR. Awareness and ever-use of electronic cigarettes among U.S. adults, 2010–2011. Nicotine & Tobacco Research. 2013;15(9):1623-7. [pmid: 23449421].
Klesges RC, Debon M, Ray JW. Are self-reports of smoking rate biased? Evidence from the Second National Health and Nutrition Examination Survey. Journal of Clinical Epidemiology. 1995;48(10):1225-33. [pmid: 7561984].
Lee JG, Griffin GK, Melvin CL. Tobacco use among sexual minorities in the USA, 1987 to May 2007: a systematic review. Tobacco Control. 2009;18(4):275-82. [pmid: 19208668].
Levine AM, Seaberg EC, Hessol NA, Preston-Martin S, Silver S, Cohen MH, Anastos K, Minkoff H, Orenstein J, Dominguez G, et al. HIV As a Risk Factor for Lung Cancer in Women: Data From the Women's Interagency HIV Study. Journal of Clinical Oncology. 2010;28(9):1514-9. [pmid: 20177022].
Ling PM, Glantz SA. Why and how the tobacco industry sells cigarettes to young adults: evidence from industry documents. American Journal of Public Health. 2002;92(6):908-16. [pmid: 12036776].
Marshall L, Schooley M, Ryan H, Cox P, Easton A, Healton C, Jackson K, Davis KC, Homsi G, Centers for Disease C, et al. Youth tobacco surveillance—United States, 2001–2002. Morbidity and Mortality Weekly Report: Surveillance Summaries. 2006;55(3):1-56. [pmid: 16708059].
Marshall MM, McCormack MC, Kirk GD. Effect of cigarette smoking on HIV acquisition, progression, and mortality. AIDS Education and Prevention. 2009;21(3 Suppl):28-39. [pmid: 19537952].
Maxwell JC Jr. Cigar Industry in 2011. Richmond (VA). John C. Maxwell, Jr. 2012.
Maxwell JC Jr. The Maxwell Report: Third Quarter 2012 Cigarette Industry. Richmond (VA). John C. Maxwell, Jr. 2012.
Maxwell JC Jr. The Smokeless Tobacco Industry in 2011. Richmond (VA). John C. Maxwell, Jr. 2012.
McMillen R, Maduka J, Winickoff J. Use of emerging tobacco products in the United States. Journal of Environmental and Public Health. 2012. [doi: 10.1155/2012/989474].
McNeill A, Bedi R, Islam S, Alkhatib MN, West R. Levels of toxins in oral tobacco products in the UK. Tobacco Control. 2006;15(1):64-7. [pmid: 16436408].
Morris DS, Tynan MA. Fiscal and policy implications of selling pipe tobacco for roll-your-own cigarettes in the United States. PloS One. 2012;7(5):e36487. [pmid: 22567159].
National Cancer Institute. Smokeless Tobacco or Health: An International Perspective. Smoking and Tobacco Control Monograph No. 2. Bethesda (MD). U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Cancer Institute. 1992. NIH Publication No. 92-3461.
National Cancer Institute. Cigars: Health Effects and Trends. Tobacco Control Monograph No. 9. Bethesda (MD). U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Cancer Institute. 1998. NIH Publication No. 98-4302.
National Center for Health Statistics. 2007 National Health Interview Survey (NHIS): Public Use Data Release: NHIS Survey Description. Hyattsville (MD). U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Health Statistics. 2008.
Nelson DE, Mowery P, Asman K, Pederson LL, O'Malley PM, Malarcher A, Maibach EW, Pechacek TF. Long-term trends in adolescent and young adult smoking in the United States: metapatterns and implications. American Journal of Public Health. 2008;98(5):905-15. [pmid: 18382001].
Nyman AL, Taylor TM, Biener L. Trends in cigar smoking and perceptions of health risks among Massachusetts adults. Tobacco Control. 2002;11(Suppl 2):ii25-ii8. [pmid: 12034977].
Ohsfeldt RL, Boyle RG, Capilouto E. Effects of tobacco excise taxes on the use of smokeless tobacco products in the USA. Health Economics. 1997;6(5):525-31. [pmid: 9353656].
Patrick DL, Cheadle A, Thompson DC, Diehr P, Koepsell T, Kinne S. The validity of self-reported smoking: a review and meta-analysis. American Journal of Public Health. 1994;84(7):1086-93. [pmid: 8017530].
Pearson JL, Richardson A, Niaura RS, Vallone DM, Abrams DB. e-Cigarette awareness, use, and harm perceptions in U.S. adults. American Journal of Public Health. 2012;102(9):1758-66. [pmid: 22813087].
Pickle LW, Su Y. Within-state geographic patterns of health insurance coverage and health risk factors in the United States. American Journal of Preventive Medicine. 2002;22(2):75-83. [pmid: 11818175].
Pines H, Koutsky L, Buskin S. Cigarette Smoking and Mortality Among HIV-Infected Individuals in Seattle, Washington (1996–2008). AIDS and Behavior. 2011;15(1):243-51. [pmid: 20390335].
Prochaska JJ, Hall SM, Bero LA. Tobacco use among individuals with schizophrenia: what role has the tobacco industry played?. Schizophrenia Bulletin. 2008;34(3):555-67. [pmid: 17984298].
Regan AK, Promoff G, Dube SR, Arrazola R. Electronic nicotine delivery systems: adult use and awareness of the “e-cigarette” in the U.S.A. Tobacco Control. 2013;22(1):19-23. [pmid: 22034071].
Rahmanian S, Wewers ME, Koletar S, Reynolds N, Ferketich A, Diaz P. Cigarette smoking in the HIV-infected population. Proceedings of the American Thoracic Society. 2011;8(3):313-9. [pmid: 21653534].
Richter P, Spierto FW. Surveillance of smokeless tobacco nicotine, pH, moisture, and unprotonated nicotine content. Nicotine & Tobacco Research. 2003;5(6):885-9. [pmid: 14668072].
Ryan H, Trosclair A, Gfroerer J. Adult current smoking: differences in definitions and prevalence estimates—NHIS and NSDUH, 2008. Journal of Environmental and Public Health. 2012;2012:918368. [pmid: 22649464].
Schinke SP, Schilling RF 2nd, Gilchrist LD, Ashby MR, Kitajima E. Pacific northwest native American youth and smokeless tobacco use. International Journal of the Addictions. 1987;22(9):881-4. [pmid: 3500137].
Schroeder SA, Morris CD. Confronting a neglected epidemic: tobacco cessation for persons with mental illnesses and substance abuse problems. Annual Review of Public Health. 2010;31:297-314.
Stehr M. Cigarette tax avoidance and evasion. Journal of Health Economics. 2005;24(2):277-97. [pmid: 15721046].
Stepanov I, Jensen J, Hatsukami D, Hecht SS. Tobacco-specific nitrosamines in new tobacco products. Nicotine & Tobacco Research. 2006;8(2):309-13. [pmid: 16766423].
Substance Abuse and Mental Health Services Administration. The NSDUH Report: Substance Use Among 12th Grade Aged Youth by Dropout Status. Rockville (MD). Center for Behavioral Health Statistics and Quality. 2013.
Tesoriero JM, Gieryic SM, Carrascal A, Lavigne HE. Smoking among HIV positive New Yorkers: prevalence, frequency, and opportunities for cessation. AIDS and Behavior. 2010;14(4):824-35. [pmid: 18777131].
Trinidad DR, Perez-Stable EJ, Emery SL, White MM, Grana RA, Messer KS. Intermittent and light daily smoking across racial/ethnic groups in the United States. Nicotine & Tobacco Research. 2009;11(2):203-10. [pmid: 19246433].
Turner CF, Lessler JT, Devore J. Effects of mode of administration and wording on reporting of drug use. Turner CF, Lessler JT, Gfroerer J, editors. Survey Measurement of Drug Use: Methodological Studies. Rockville (MD). U.S. Department of Health and Human Services, Public Health Service, Substance Abuse and Mental Health Services Administration. 1992:177-219. DHHS Publication No. (ADM) 92-1929.
U.S. Department of Agriculture. Tobacco Outlook. TBS-263. Washington. U.S. Department of Agriculture, Economics Research Service. 2007. <http://usda.mannlib.cornell.edu/usda/ers/TBS//2000s/2007/TBS-10-24-2007.pdf>. July 15, 2013.
U.S. Department of Health and Human Services. Reducing the Health Consequences of Smoking: 25 Years of Progress. A Report of the Surgeon General. Rockville (MD). U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 1989. DHHS Publication No. (CDC) 89-8411.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Young People: A Report of the Surgeon General. Atlanta (GA). U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 1994.
U.S. Department of Health and Human Services. Tobacco Use Among U.S. Racial/Ethnic Minority Groups-African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics. A Report of the Surgeon General. Atlanta (GA). U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 1998.
U.S. Department of Health and Human Services. Reducing Tobacco Use. A Report of the Surgeon General. Atlanta (GA). U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 2000.
U.S. Department of Health and Human Services. The Health Consequences of Smoking: A Report of the Surgeon General. Atlanta (GA). U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 2004.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta (GA). U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 2012.
U.S. Department of Treasury, The Alcohol and Tobacco Tax and Trade Bureau. Tobacco Statistics 2012. 2012. <http://www.ttb.gov/tobacco/tobacco-stats.shtml>. April 30, 2013.
Velicer WF, Prochaska JO, Rossi JS, Snow MG. Assessing outcome in smoking cessation studies. Psychological Bulletin. 1992;111(1):23-41. [pmid: 1539088].
Vidrine DJ. Cigarette smoking and HIV/AIDS: health implications, smoker characteristics and cessation strategies. AIDS Education and Prevention. 2009;21(3 Suppl):3-13. [pmid: 19537950].
Villanti AC, German D, Sifakis F, Flynn C, Holtgrave D. Smoking, HIV Status, and HIV Risk Behaviors in a Respondent-Driven Sample of Injection Drug Users in Baltimore, Maryland: The BeSure Study. AIDS Education and Prevention. 2012;24(2):132-47. [pmid: 22468974].
Warner KE, Murt HA. Impact of the antismoking campaign on smoking prevalence: a cohort analysis. Journal of Public Health Policy. 1982;3(4):374-90. [pmid: 7153358].
Young D, Yong HH, Borland R, Shahab L, Hammond D, Cummings KM, Wilson N. Trends in roll-your-own smoking: findings from the ITC Four-Country Survey (2002–2008). Journal of Environmental and Public Health. 2012;2012. 406283.