# List of Abbreviations

4-ABP: 4-aminobiphenyl
AAP: American Academy of Pediatrics
AAT: α-1 antitrypsin
ACE: acute coronary events
ACOG: American Congress of Obstetricians and Gynecologists
ACS: American Cancer Society
ADHD: attention deficit hyperactivity disorder
AMA: American Medical Association
AMD: age-related macular degeneration
AMI: acute myocardial infarction
anti-CCP: anti-cyclic citrullinated peptide
anti-HCV: antibodies to hepatitis C virus
ANR: Americans for Nonsmokers' Rights
ANRF: American Nonsmokers' Rights Foundation
AOR: adjusted odds ratio
ARIC: Atherosclerosis Risk in Communities
ASSIST: American Stop Smoking Intervention Study
ATS: American Thoracic Society
B[a]P: benzo[a]pyrene
BACH: Boston Area Community Health survey
BALT: bronchus-associated lymphoid tissue
BAT: British American Tobacco
BCFR: Breast Cancer Family Registry
BMI: body mass index
Breg: B regulatory cells
BRFSS: Behavioral Risk Factor Surveillance System
B&W: Brown & Williamson Tobacco Co.
Cal/EPA: California Environmental Protection Agency
CBCL: child behavior checklist
CBO: Congressional Budget Office
CC16: Clara cell secretory protein 16
CDC: Centers for Disease Control and Prevention
CF: cystic fibrosis
CFTR: cystic fibrosis transmembrane conductance regulator
CHARGE: Cohorts for Heart and Aging Research in Genomic Epidemiology
CHD: coronary heart disease
CHF: congestive heart failure
CI: confidence interval
CISNET: Cancer Intervention and Surveillance Modeling Network
CL/P: cleft lip with or without cleft palate
CLUE II: Campaign Against Cancer and Heart Disease
cm: centimeter
CMS: Centers for Medicare & Medicaid Services
CNS: central nervous system
CNV: choroidal neovascularization
CO: carbon monoxide
COLD: chronic obstructive lung disease
COMMIT: Community Intervention Trial for Smoking Cessation
COPD: chronic obstructive pulmonary disease
COSMIC: Catalogue of Somatic Mutations in Cancer
CP: cleft palate
CPP: Collaborative Perinatal Project
CPS: Cancer Prevention Study
CRP: C-reactive protein
CSE: cigarette smoke extract
CT: computed tomography
CTR: The Council for Tobacco Research—U.S.A., Inc.
CVD: cardiovascular disease
CYP: cytochrome P-450
DALYs: disability-adjusted life years
DAMPs: damage-associated molecular patterns
DFS: decayed/filled tooth surface
DFT: decayed/filled permanent teeth
dL: deciliter
DMF: decayed/missing due to caries/filled
DMFS: decayed/missing due to caries/filled tooth surface
DMFT: decayed/missing due to caries/filled permanent teeth
DOD: U.S. Department of Defense
DOJ: U.S. Department of Justice
DTPs: dissolvable tobacco products
E1: estrone
E2: estradiol
E3: estriol
ECLIPSE: Evaluation of COPD Longitudinally to Identify Predictive Surrogate Endpoints
ED: erectile dysfunction
EGRCIBD-Japan: Epidemiology Group of the Research Committee of Inflammatory Bowel Disease in Japan
EHR: electronic health record
ENDS: electronic nicotine delivery system
EP: ectopic pregnancy
EPA: U.S. Environmental Protection Agency
EPIC: European Prospective Investigation into Cancer and Nutrition
ER: estrogen receptor
ETS: environmental tobacco smoke
FCA: Framework Convention Alliance
FCC: Federal Communications Commission
FCTC: Framework Convention on Tobacco Control
FDA: U.S. Food and Drug Administration
FEV_1_: forced expiratory volume in 1 second
FMD: flow-mediated dilation
FOXP3: forkhead box PC
FTC: U.S. Federal Trade Commission
FVC: forced vital capacity
g: gram
GA: geographic atrophy
GABA: gamma-aminobutyric acid
GAO: U.S. Government Accounting Office
GATS: Global Adult Tobacco Survey
GENICA: Gene Environment Interaction and Breast Cancer
GenKOLS: Genetics of Chronic Obstructive Lung Disease
GINA: Global Initiative for Asthma
GM-CSF: granulocyte macrophage colony-stimulating factor
GOLD: Global Initiative for Chronic Obstructive Lung Disease
GSP: Global Smokefree Partnership
GST: glutathione S-transferase
GWAS: genome-wide association studies
HBV: hepatitis B virus
HBsAg: HBV surface antigen
HCC: hepatocellularcarcinoma
HCV: hepatitis C virus
Hg: mercury
HIP: Health Insurance Plan
HITECH: Health Information Technology Economic and Clinical Health Act
HIV/AIDS: human immunodeficiency virus infection/acquired immunodeficiency syndrome
HMGB1: high mobility group box 1
HMOX: heme oxygenase
HPHCs: harmful and potentially harmful constituents [in tobacco products]
HPV: human papillomavirus
HR: hazard ratio
HRS: Health and Retirement Study
HRT: hormone replacement therapy
HSPs: heat shock proteins
IARC: International Agency for Research on Cancer
IBD: inflammatory bowel disease
ICD: International Classification of Diseases
IFN: interferon
IFNγ: interferon gamma
Ig: immunoglobulin
IgG: immunoglobulin G
IHD: ischemic heart disease
IIEF: International Index of Erectile Function
IL: interleukin
IMPACT: Initiatives to Mobilize for the Prevention and Control of Tobacco Use Program
IOM: Institute of Medicine
IPF: idiopathic pulmonary fibrosis
IQ: intelligence quotient
IUD: intrauterine device
IUGR: intrauterine growth retardation
JNK: c-Jun N-terminal kinase
LD50: dose causing 50% lethality
LMIC: low- and middle-income countries
LPS: lipopolysaccharide
M. tuberculosis: Mycobacterium tuberculosis
mcg: micrograms
MEPS: Medical Expenditure Panel Survey
MeSH: Medical Subject Headings
mg: milligram
MHC: major histocompatibility complex
MI: myocardial infarction
mL: milliliter
mm: millimeter
mmol: millimole
mmol/L: millimoles per liter
MMP: matrix metalloproteinase
MRFIT: Multiple Risk Factor Intervention Trial
mRNA: messenger RNA
MSA: Master Settlement Agreement
MyD88: myeloid differentiation factor 88
nAChR: nicotinic acetylcholine receptor
NAQC: North American Quitline Consortium
NAT: N-acetyltransferase
NBDPS: National Birth Defects Prevention Study
NCHS: National Center for Health Statistics
NCI: National Cancer Institute
NE: neutrophil elastase
NETT: National Emphysema Treatment Trial
NF-κB: nuclear factor-kappa B
NFPA: National Fire Protection Association
ng: nanogram
NHANES: National Health and Nutrition Examination Survey
NHDS: National Hospital Discharge Survey
NHIS: National Health Interview Survey
NHLBI: National Heart, Lung, and Blood Institute
NHS: Nurses' Health Study
NIDA: National Institute on Drug Abuse
NIH: National Institutes of Health
NK: natural killer
NKG2D: NK group 2D
NKT: natural killer T
NNAL: 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol
NNK: 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone
NNN: N´-nitrosonornicotine
NO: nitric oxide
NP: nicotine polacrilex gum
NPCR: National Program of Cancer Registries
NPT: nocturnal penile tumescence
NPTR: nocturnal penile tumescence and rigidity
NRT: nicotine replacement therapy
NSAIDs: nonsteroidal anti-inflammatory drugs
NSCLC: non-small-cell lung cancer
NSDUH: National Survey on Drug Use and Health
NTHi: nontypeable Haemophilus influenza
NV: neovascular
NYTS: National Youth Tobacco Survey
ODD: oppositional defiant disorder
OR: odds ratio
P. aeruginosa: Pseudomonas aeruginosa
PACT: Prevent All Cigarette Trafficking Act
PAD: peripheral arterial disease
PAF: population-attributable fraction
PAH: polycyclic aromatic hydrocarbon
PAI-1: plasminogen activator inhibitor-1
PAMPs: pathogen-associated molecular patterns
Pap: Papanicolaou
PARC: pulmonary-and activation-regulated chemokine
PBI: penile-brachial index
PCR: polymerase chain reaction
PDAY: Pathobiological Determinants of Atherosclerosis in Youth study
PHS: U.S. Public Health Service
PID: pelvic inflammatory disease
PM_2.5_: particulate matter
PR: progesterone receptors
PRAMS: Pregnancy Risk Assessment Monitoring System
PRRs: pattern recognition receptors
PSA: prostate-specific antigen
PSAM: probability of smoking-attributable mortality
PVFE: present value of future earnings
QALYs: quality-adjusted life years
RA: rheumatoid arthritis
RAI: Reynolds American, Inc.
RCP: Royal College of Physicians
RCT: randomized clinical trial
RDFS: root-surface caries decayed/filled tooth surface
RDS: root-surface caries decayed tooth surface
RF: rheumatoid factor
RICO: Racketeer Influenced and Corrupt Organizations Act
RJR: R.J. Reynolds Tobacco Company
ROS: reactive-oxygen species
RPE: retinal pigment epithelium
RR: relative risk
RSV: respiratory syncytial virus
RT: response time
S. pneumonia: Streptococcus pneumoniae
SAB: spontaneous abortion
SAF: smoking-attributable fraction
SAM: smoking-attributable mortality
SAMHSA: Substance Abuse and Mental Health Services Administration
SAMMEC: Smoking-Attributable Mortality, Morbidity, and Economic Costs
SCD: sudden coronary death
SCE: sister chromatid exchange
SEER: Surveillance, Epidemiology, and End Results
SES: socioeconomic status
SF-12: Short Form 12
SF-36: Short Form 36
sFlt-1: soluble fms-like tyrosine kinase-1
S/G_2_/M: synthesis/gap_2_/mitosis
SIDS: sudden infant death syndrome
SLE: systemic lupus erythematosus
SLEDAI: Systemic Lupus Erythematosus Disease Activity Index
SNP: single nucleotide polymorphism
SOD2: superoxide dismutase 2
STI: sexually transmitted infection
SULT: sulfotransferase
TB: tuberculosis
TCDD: tetrachlorodibenzo-p-dioxin
TCR: T cell receptor
Th cell: T helper cell
TI: The Tobacco Institute, Inc.
TIA: transient ischemic attack
TIPS: Tips from Former Smokers
TIRC: Tobacco Industry Research Committee
TLR4: toll-like receptor 4
tPA: tissue plasminogen activator
TPSAC: Tobacco Products Scientific Advisory Committee
TRIPS: Trade-Related Aspects of Intellectual Property Rights
TRPA1: transient receptor patential cation channel, subfamily A, member 1
TST: tuberculin skin test
UGT: uridine-5′-disphosphate-glucuronosyltransferase
UICC: Union for International Cancer Control
UN: United Nations
UPRs: unfolded protein responses
USDHEW: U.S. Department of Health, Education, and Welfare
USDHHS: U.S. Department of Health and Human Services
USEPA: U.S. Environmental Protection Agency
USGAO: U.S. General Accounting Office
USPSTF: U.S. Preventive Services Task Force
USRTC: U.S. Radiologic Technologist Cohort
VA: U.S. Department of Veterans Affairs
VDJ: variable, diversity, and joining gene segments recombination
WHI: Women's Health Initiative
WHO: World Health Organization
WTO: World Trade Organization
YPLL: years of potential life lost
YRBS: Youth Risk Behavior Survey
YRBSS: Youth Risk Behavior Surveillance System