# References

1 World Health Organization. (2023, February 21). Stress. World Health Organization. https://www.who.int/news-room/questions-and-answers/item/stress
2 Centers for Disease Control and Prevention. (2024, April 16). About Mental Health. U.S. Department of Health & Human Services. https://www.cdc.gov/mentalhealth/learn/index.htm
3 Substance Abuse and Mental Health Services Administration. (2023, April 24). What is Mental Health?. U.S. Department of Health & Human Services. https://www.samhsa.gov/mental-health
4 U.S. Census Bureau. (2023, November 14). Parents’ Living Arrangements. https://www.census.gov/library/visualizations/interactive/parents-living-arrangements.html
5 The Annie E. Casey Foundation. (2023, September). Children in Kinship Care in United States. https://datacenter.aecf.org/data/tables/10455-children-in-kinship-care?loc=1&loct=1#detailed/1/any/false/2554,2479,2097,1985,1757/any/20160,20161
6 The Recognize, Assist, Include, Support, and Engage (RAISE) Act, Family Caregiving Advisory Council & The Advisory Council to Support Grandparents Raising Grandchildren. (2022, September 21). 2022 National Strategy to Support Family Caregivers. Administration for Community Living. https://acl.gov/sites/default/files/RAISE_SGRG/NatlStrategyToSupportFamilyCaregivers-2.pdf
7 Nelson, S. K., Kushlev, K., & Lyubomirsky, S. (2014). The pains and pleasures of parenting: when, why, and how is parenthood associated with more or less well-being?. Psychological bulletin, 140(3), 846–895. 10.1037/a0035444 24491021
8 American Psychological Association. (2022, October 31). How stress effects your health. https://www.apa.org/topics/stress/health
9 Ramanathan, R., & Desrouleaux, R. (2022). Introduction: The Science of Stress. The Yale Journal of Biology and Medicine, 95(1), 1–2. https://www.ncbi.nlm.nih.gov/pmc/articles/PMC8961711/
10 Lu, S., Wei, F., & Li, G. (2021). The evolution of the concept of stress and the framework of the stress system. Cell stress, 5(6), 76–85. 10.15698/cst2021.06.250 34124582
11 Pardini D. A. (2008). Novel insights into longstanding theories of bidirectional parent-child influences: introduction to the special section. Journal of abnormal child psychology, 36(5), 627–631. 10.1007/s10802-008-9231-y 18437550
12 Brooker, R. J., Neiderhiser, J. M., Leve, L. D., Shaw, D. S., Scaramella, L. V., & Reiss, D. (2015). Associations Between Infant Negative Affect and Parent Anxiety Symptoms are Bidirectional: Evidence from Mothers and Fathers. Frontiers in psychology, 6, 1875. 10.3389/fpsyg.2015.01875 26696939
13 Pérez-Edgar, K., LoBue, V., & Buss, K. A. (2021). From parents to children and back again: Bidirectional processes in the transmission and development of depression and anxiety. Depression and anxiety, 38(12), 1198–1200. 10.1002/da.23227 34878704
14 Thompson, A. J., & Henrich, C. C. (2022). Cross-lagged effects between parent depression and child internalizing problems. Journal of family psychology : JFP : journal of the Division of Family Psychology of the American Psychological Association (Division 43), 36(8), 1428–1438. 10.1037/fam0001012 35737538
15 American Psychological Association. (2024, July 12). Parental burnout and stress. https://www.apa.org/topics/stress/parental-burnout
16 American Psychological Association (2023, November). Infographic: Stress of parents compared to other adults. https://www.apa.org/news/press/releases/stress/2023/infographics/infographic-parents-other-adults
17 Lebrun-Harris, L. A., Ghandour, R. M., Kogan, M. D., & Warren, M. D. (2022). Five-Year Trends in US Children’s Health and Well-being, 2016-2020. JAMA pediatrics, 176(7), e220056. 10.1001/jamapediatrics.2022.0056 35285883
18 Czeisler, M. É., Rohan, E. A., Melillo, S., Matjasko, J. L., DePadilla, L., Patel, C. G., Weaver, M. D., Drane, A., Winnay, S. S., Capodilupo, E. R., Robbins, R., Wiley, J. F., Facer-Childs, E. R., Barger, L. K., Czeisler, C. A., Howard, M. E., & Rajaratnam, S. M. W. (2021). Mental Health Among Parents of Children Aged <18 Years and Unpaid Caregivers of Adults During the COVID-19 Pandemic — United States, December 2020 and February–March 2021. MMWR. Morbidity and mortality weekly report, 70(24), 879–887. 10.15585/mmwr.mm7024a3 34138835
19 Nomaguchi, K., & Milkie, M. A. (2020). Parenthood and Well-Being: A Decade in Review. Journal of marriage and the family, 82(1), 198–223. 10.1111/jomf.12646 32606480
20 Hagen, E. W., Mirer, A. G., Palta, M., & Peppard, P. E. (2013). The sleep-time cost of parenting: sleep duration and sleepiness among employed parents in the Wisconsin Sleep Cohort Study. American journal of epidemiology, 177(5), 394–401. 10.1093/aje/kws246 23378502
21 Collins, W. A., & Madsen, S. D. (2019). Parenting during middle childhood. In M. H. Bornstein (Ed.), Handbook of parenting: Children and parenting (3rd ed., pp. 81–110). Routledge/Taylor & Francis Group. 10.4324/9780429440847-3
22 Branje, S. (2018). Development of parent–adolescent relationships: Conflict interactions as a mechanism of change. Child Development Perspectives, 12(3), 171–176. 10.1111/cdep.12278
23 World Health Organization (n.d.). Adolescent Health. https://www.who.int/health-topics/adolescent-health#tab=tab_1
24 Reich-Stiebert, N., Froehlich, L., & Voltmer, J. B. (2023). Gendered Mental Labor: A Systematic Literature Review on the Cognitive Dimension of Unpaid Work Within the Household and Childcare. Sex roles, 88(11–12), 475–494. 10.1007/s11199-023-01362-0 37283733
25 Kalil, A., & Ryan, R. (2020). Parenting practices and socioeconomic gaps in childhood outcomes. The Future of Children, 30(1), 29–54.
26 The White House. (2023, April 18). Executive Order on Increasing Access to High-Quality Care and Supporting Caregivers. https://www.whitehouse.gov/briefing-room/presidential-actions/2023/04/18/executive-order-on-increasing-access-to-high-quality-care-and-supporting-caregivers/
27 Braga, D. (2022, December 7). One-in-four U.S. parents say they’ve struggled to afford food or housing in the past year. Pew Research Center. https://www.pewresearch.org/short-reads/2022/12/07/one-in-four-u-s-parents-say-theyve-struggled-to-afford-food-or-housing-in-the-past-year/
28 Quint, J., Griffin, K. M., Kaufman, J., Landers, P., & Utterback, A. (2018). Experiences of Parents and Children Living in Poverty: A Review of the Qualitative Literature. OPRE Report 2018-30. Washington, DC: Office of Planning, Research, and Evaluation, Administration for Children and Families, U.S. Department of Health and Human Services.
29 Cain, K. S., Meyer, S. C., Cummer, E., Patel, K. K., Casacchia, N. J., Montez, K., Palakshappa, D., & Brown, C. L. (2022). Association of Food Insecurity with Mental Health Outcomes in Parents and Children. Academic pediatrics, 22(7), 1105–1114. 10.1016/j.acap.2022.04.010 35577282
30 U.S. Bureau of Labor Statistics (BLS). (n.d.). One-Screen Data Search: American Time Use Survey. U.S. Department of Labor. https://data.bls.gov/PDQWeb/tu
31 Bianchi, S. M. (2011). Family change and time allocation in American families. Annals of the American Academy of Political and Social Science, 638(1), 21–44. 10.1177/0002716211413731
32 Allard, M. D., Bianchi, S., Stewart, J., & Wight, V. R. (2007). Comparing childcare measures in the ATUS and earlier time-diary studies. Monthly Labor Review, 130(5), 27–36. http://www.jstor.org/stable/23806949
33 Foucreault, A., Ménard, J., Houlfort, N., Trépanier, S. G., & Lavigne, G. L. (2023). How Work-Family Guilt, Involvement with Children and Spouse’s Support Influence Parents’ Life Satisfaction in a Context of Work-Family Conflict. Journal of child and family studies, 32(4), 1065–1077. 10.1007/s10826-022-02443-6 36186677
34 U.S. Bureau of Labor Statistics (BLS). (2024, June 27). American Time Use Survey Technical Note. U.S. Department of Labor. https://www.bls.gov/news.release/atus.tn.htm
35 U.S. Bureau of Labor Statistics (BLS). (n.d.). Average hours per day parents spent caring for and helping household children as their main activity. U.S. Department of Labor. https://www.bls.gov/charts/american-time-use/activity-by-parent.htm
36 Horowitz, J. M. (2022, April 8). More than half of Americans in their 40s are ”sandwiched’ between an aging parent and their own children. Pew Research Center. https://www.pewresearch.org/short-reads/2022/04/08/more-than-half-of-americans-in-their-40s-are-sandwiched-between-an-aging-parent-and-their-own-children/
37 Lei, L., Leggett, A. N., & Maust, D. T. (2023). A national profile of sandwich generation caregivers providing care to both older adults and children. Journal of the American Geriatrics Society, 71(3), 799–809. 10.1111/jgs.18138 36427297
38 Al Yahyaei, A., Al Omari, O., Abu Sharour, L., Cayaban, A. R., Shebani, Z., Al Hashmi, I., ALBashtawy, M., Alkhawaldeh, A., & Alhalaiqa, F. (2024). The Lived Experience of Parent Caregivers of Adolescents with Mental Illness: A Phenomenological Study. International journal of community based nursing and midwifery, 12(1), 2–12. 10.30476/IJCBNM.2023.100667.2375 38328010
39 Minkin, R., & Menasce Horowitz, J. (2023, January 24). Parenting in America Today. Pew Research Center. https://www.pewresearch.org/social-trends/2023/01/24/parenting-in-america-today/
40 Lindo, E. J., Kliemann, K. R., Combes, B. H., & Frank, J. (2016). Managing Stress Levels of Parents of Children with Developmental Disabilities: A Meta-Analytic Review of Interventions. Family Relations, 65(1), 207–224. https://doi-org.hhsnih.idm.oclc.org/10.1111/fare.12185
41 Scherer, N., Verhey, I., & Kuper, H. (2019). Depression and anxiety in parents of children with intellectual and developmental disabilities: A systematic review and meta-analysis. PloS one, 14(7): e0219888. 10.1371/journal.pone.0219888 31361768
42 Health Resources and Services Administration (HRSA), Maternal and Child Health Bureau (MCHB). (2020 July). Children with Special Healthcare Needs NSCH Data Brief. https://mchb.hrsa.gov/sites/default/files/mchb/programs-impact/nsch-cshcn-data-brief.pdf
43 Child and Adolescent Health Measurement Initiative. 2016-2017 National Survey of Children’s Health (NSCH) data query [Data set]. Data Resource Center for Child and Adolescent Health supported by the U.S. Department of Health and Human Services, Health Resources and Services Administration (HRSA), Maternal and Child Health Bureau (MCHB). https://nschdata.org/browse/survey/results?q=8440&g=879
44 Pew Research Center. (2015, December 17). Parenting in America: Parenting approaches and concerns. https://www.pewresearch.org/social-trends/2015/12/17/3-parenting-approaches-and-concerns/
45 Office of the Surgeon General (OSG). (2024). Firearm Violence: A Public Health Crisis in America: The U.S. Surgeon General’s Advisory. US Department of Health and Human Services. https://www.hhs.gov/sites/default/files/firearm-violence-advisory.pdf
46 Jones, J. (2023, August 31). School, parent safety concerns remain high. Gallup. https://news.gallup.com/poll/510398/school-parent-safety-concerns-remain-high.aspx
47 American Psychological Association. (2018). Stress in America™: Generation Z. https://www.apa.org/news/press/releases/stress/2018/stress-gen-z.pdf
48 Office of the Surgeon General (OSG). (2023). Our Epidemic of Loneliness and Isolation: The U.S. Surgeon General’s Advisory on the Healing Effects of Social Connection and Community. US Department of Health and Human Services. https://www.hhs.gov/sites/default/files/surgeon-general-social-connection-advisory.pdf
49 Cigna Corporation. (n.d.). The Loneliness Epidemic Persists: A Post Pandemic Look at the State of Loneliness among U.S. Adults. https://newsroom.thecignagroup.com/loneliness-epidemic-persists-post-pandemic-look
50 Auxier, B., Anderson, M., Perrin, A., & Turner, E. (2020, July 28). Parenting Children in the Age of Screens. Pew Research Center: Internet, Science & Tech. https://www.pewresearch.org/internet/2020/07/28/parenting-children-in-the-age-of-screens/
51 Gelles-Watnick, R. (2022, December 15). Explicit Content, Time-wasting Are Key Social Media Worries For Parents Of U.S. Teens. Pew Research Center. https://www.pewresearch.org/fact-tank/2022/12/15/explicit-content-time-wasting-are-key-social-media-worries-for-parents-of-u-s-teens/
52 Nomaguchi, K., & Milkie, M. A. (2017). Sociological perspectives on parenting stress: How social structure and culture shape parental strain and the well-being of parents and children. In K. Deater-Deckard & R. Panneton (Eds.), Parental stress and early child development: Adaptive and maladaptive outcomes (pp. 47–73). Springer International Publishing. 10.1007/978-3-319-55376-4_3
53 Ghaleiha, A., Barber, C., Tamatea, A. J., & Bird, A. (2022). Fathers’ help seeking behavior and attitudes during their transition to parenthood. Infant mental health journal, 43(5), 756–768. 10.1002/imhj.22008 35913697
54 Ishizuka, P. (2019). Social Class, Gender, and Contemporary Parenting Standards in the United States: Evidence from a National Survey Experiment. Social Forces, 98(1), 31–58. 10.1093/sf/soy107
55 Grzywacz, J. G., & Bass, B. L. (2003). Work, Family, and Mental Health: Testing Different Models of Work-Family Fit. Journal of Marriage and Family, 65(1), 248–261. http://www.jstor.org/stable/3600063
56 Sayer, L. C., Bianchi, S. M., & Robinson, J. P. (2004). Are Parents Investing Less in Children? Trends in Mothers’ and Fathers’ Time with Children. American Journal of Sociology, 110(1), 1–43. 10.1086/386270
57 Kwon, S., O’Neill, M. E., & Foster, C. C. (2022). The Associations of Child’s Clinical Conditions and Behavioral Problems with Parenting Stress among Families of Preschool-Aged Children: 2018-2019 National Survey of Child Health. Children (Basel, Switzerland), 9(2), 241. 10.3390/children9020241 35204961
58 Office of the Surgeon General (OSG). (2023). Social Media and Youth Mental Health: The U.S. Surgeon General’s Advisory. US Department of Health and Human Services. https://www.hhs.gov/sites/default/files/sg-youth-mental-health-social-media-advisory.pdf
59 Tsuang, M. T., Bar, J. L., Stone, W. S., & Faraone, S. V. (2004). Gene-environment interactions in mental disorders. World psychiatry : official journal of the World Psychiatric Association (WPA), 3(2), 73–83.16633461
60 Schmidt C. W. (2007). Environmental connections: a deeper look into mental illness. Environmental health perspectives, 115(8), A404–A410. 10.1289/ehp.115-a404 17687431
61 Merrick, M. T., Ports, K. A., Ford, D. C., Afifi, T. O., Gershoff, E. T., & Grogan-Kaylor, A. (2017). Unpacking the impact of adverse childhood experiences on adult mental health. Child abuse & neglect, 69, 10–19. 10.1016/j.chiabu.2017.03.016 28419887
62 Uher, R., & Zwicker, A. (2017). Etiology in psychiatry: embracing the reality of poly-gene-environmental causation of mental illness. World psychiatry : official journal of the World Psychiatric Association (WPA), 16(2), 121–129. 10.1002/wps.20436 28498595
63 National Institutes of Health, NIH Curriculum Supplement Series [Internet]. (2007). Information about Mental Illness and the Brain. Biological Sciences Curriculum Study. https://www.ncbi.nlm.nih.gov/books/NBK20369/
64 Yim, I. S., Tanner Stapleton, L. R., Guardino, C. M., Hahn-Holbrook, J., & Dunkel Schetter, C. (2015). Biological and psychosocial predictors of postpartum depression: systematic review and call for integration. Annual review of clinical psychology, 11, 99–137. 10.1146/annurev-clinpsy-101414-020426
65 Nestler, E. J., Peña, C. J., Kundakovic, M., Mitchell, A., & Akbarian, S. (2016). Epigenetic Basis of Mental Illness. The Neuroscientist : a review journal bringing neurobiology, neurology and psychiatry, 22(5), 447–463. 10.1177/1073858415608147 26450593
66 McGowan, P. O., & Szyf, M. (2010). The epigenetics of social adversity in early life: implications for mental health outcomes. Neurobiology of disease, 39(1), 66–72. 10.1016/j.nbd.2009.12.026 20053376
67 Kundakovic, M., & Rocks, D. (2022). Sex hormone fluctuation and increased female risk for depression and anxiety disorders: From clinical evidence to molecular mechanisms. Frontiers in neuroendocrinology, 66, 101010. 10.1016/j.yfrne.2022.101010 35716803
68 Johnson, J. M., Nachtigall, L. B., & Stern, T. A. (2013). The effect of testosterone levels on mood in men: a review. Psychosomatics, 54(6), 509–514. 10.1016/j.psym.2013.06.018 24016385
69 Feder, A., Nestler, E. J., & Charney, D. S. (2009). Psychobiology and molecular genetics of resilience. Nature reviews. Neuroscience, 10(6), 446–457. 10.1038/nrn2649 19455174
70 Center for Behavioral Health Statistics and Quality. (2024). Results from the 2021-2022 National Survey on Drug Use and Health: [Special Data Analyses]. Substance Abuse and Mental Health Services Administration.
71 Zietz, S., Lansford, J. E., Liu, Q., Long, Q., Oburu, P., Pastorelli, C., Sorbring, E., Skinner, A. T., Steinberg, L., Tapanya, S., Tirado, L. M. U., Yotanyamaneewong, S., Alampay, L. P., Al-Hassan, S. M., Bacchini, D., Bornstein, M. H., Chang, L., Deater-Deckard, K., Di Giunta, L., Dodge, K. A., … Gurdal, S. (2022). A Longitudinal Examination of the Family Stress Model of Economic Hardship in Seven Countries. Children and youth services review, 143, 106661. 10.1016/j.childyouth.2022.106661 36339096
72 D’Angelo, D. V., Bombard, J. M., Lee, R. D., Kortsmit, K., Kapaya, M., & Fasula, A. (2022). Prevalence of experiencing physical, emotional, and sexual violence by a current intimate partner during pregnancy: Population-based estimates from the Pregnancy Risk Assessment Monitoring System. Journal of Family Violence, 38(1), 117–126. 10.1007/s10896-022-00356-y 37205924
73 Brown, S. J., Conway, L. J., FitzPatrick, K. M., Hegarty, K., Mensah, F. K., Papadopoullos, S., Woolhouse, H., Giallo, R., & Gartland, D. (2020). Physical and mental health of women exposed to intimate partner violence in the 10 years after having their first child: an Australian prospective cohort study of first-time mothers. BMJ open, 10(12), e040891. 10.1136/bmjopen-2020-040891
74 Stolper, H., van Doesum, K., & Steketee, M. (2021). How to Support Parents of Infants and Young Children in Mental Health Care: A Narrative Review. Frontiers in psychology, 12, 745800. 10.3389/fpsyg.2021.745800 34867627
75 Reczek C. (2020). Sexual- and Gender-Minority Families: A 2010 to 2020 Decade in Review. Journal of marriage and the family, 82(1), 300–325. 10.1111/jomf.12607 33273747
76 Milavetz, Z., Pritzl, K., Muentner, L., & Poehlmann–Tynan, J. (2021). Unmet mental health needs of jailed parents with young children. Family Relations: An Interdisciplinary Journal of Applied Family Studies, 70(1), 130–145. 10.1111/fare.12525
77 Garland McKinney, J. L., & Meinersmann, L. M. (2023). The cost of intersectionality: Motherhood, mental health, and the state of the country. Journal of Social Issues, 79(2), 596–616. 10.1111/josi.12539
78 Williams, D. R., Lawrence, J. A., & Davis, B. A. (2019). Racism and Health: Evidence and Needed Research. Annual review of public health, 40, 105–125. 10.1146/annurev-publhealth-040218-043750
79 Centers for Disease Control and Prevention (2024, June 20). Racism and Health. U.S. Department of Health and Human Services. https://www.cdc.gov/minority-health/racism-health/
80 Ridley, M., Rao, R., Schilbach, F., & Patel, V. (2021). Poverty, depression, and anxiety: Causal evidence and mechanisms. Science, 370(6522). https://economics.mit.edu/sites/default/files/2022-09/poverty-depression-anxiety-science.pdf
81 Marbin, D., Gutwinski, S., Schreiter, S., & Heinz, A. (2022). Perspectives in poverty and mental health. Frontiers in public health, 10, 975482. 10.3389/fpubh.2022.975482 35991010
82 Wildeman, C., Schnittker, J., & Turney, K. (2012). Despair by Association? The Mental Health of Mothers with Children by Recently Incarcerated Fathers. American Sociological Review, 77(2), 216–243. 10.1177/0003122411436234
83 National Institute of Mental Health. (2023, March). Mental Illness. U.S. Department of Health and Human Services. https://www.nimh.nih.gov/health/statistics/mental-illness
84 Bauman, B. L., Ko, J. Y., Cox, S., D’Angelo Mph, D. V., Warner, L., Folger, S., Tevendale, H. D., Coy, K. C., Harrison, L., & Barfield, W. D. (2020). Vital Signs: Postpartum Depressive Symptoms and Provider Discussions About Perinatal Depression - United States, 2018. MMWR. Morbidity and mortality weekly report, 69(19), 575–581. 10.15585/mmwr.mm6919a2 32407302
85 Haight, S. C., Daw, J. R., Martin, C. L., Sheffield-Abdullah, K., Verbiest, S., Pence, B. W., & Maselko, J. (2024). Racial and Ethnic Inequities in Postpartum Depressive Symptoms, Diagnosis, and Care In 7 US Jurisdictions. Health affairs (Project Hope), 43(4), 486–495. 10.1377/hlthaff.2023.01434 38560804
86 Substance Abuse and Mental Health Services Administration. (2024). The Task Force on Maternal Mental Health’s Report to Congress. U.S. Department of Health and Human Services. https://www.samhsa.gov/sites/default/files/mmh-report.pdf
87 Trost, S. L., Beauregard, J. L., Smoots, A. N., Ko, J. Y., Haight, S. C., Moore Simas, T. A., Byatt, N., Madni, S. A., & Goodman, D. (2022). Pregnancy-Related Deaths: Data from Maternal Mortality Review Committees in 36 US States, 2017-2019. Atlanta, GA: Centers for Disease Control and Prevention, US Department of Health and Human Services. https://www.cdc.gov/maternal-mortality/media/pdfs/Pregnancy-Related-Deaths-Data-MMRCs-2017-2019-H.pdf
88 Söderquist, J., Wijma, K., & Wijma, B. (2004). Traumatic stress in late pregnancy. Journal of Anxiety Disorders, 18(2), 127–142. 10.1016/S0887-6185(02)00242-6 15033212
89 O’Hara, M. W., & Wisner, K. L. (2014). Perinatal mental illness: definition, description and aetiology. Best practice & research. Clinical obstetrics & gynaecology, 28(1), 3–12. 10.1016/j.bpobgyn.2013.09.002 24140480
90 eClinicalMedicine. (2024). Safeguarding maternal mental health in the perinatal period. EClinicalMedicine, 71, 102663–102663. https://www.thelancet.com/journals/eclinm/article/PIIS2589-5370(24)00242-6/fulltext 38813440
91 Alhusen, J. L., Hayat, M. J., & Gross, D. (2013). A longitudinal study of maternal attachment and infant developmental outcomes. Archives of women’s mental health, 16(6), 521–529. 10.1007/s00737-013-0357-8
92 Branjerdporn, G., Meredith, P., Strong, J., & Garcia, J. (2017). Associations Between Maternal-Foetal Attachment and Infant Developmental Outcomes: A Systematic Review. Maternal and child health journal, 21(3), 540–553. 10.1007/s10995-016-2138-2 27456309
93 Malekpour, M. (2007). Effects of Attachment on Early and Later Development. The British Journal of Development Disabilities, 53(105), 81–95. 10.1179/096979507799103360
94 Institute of Medicine and National Research Council. (2000). From Neurons to Neighborhoods: The Science of Early Childhood Development. Washington, DC: The National Academies Press. 10.17226/9824
95 Li, J., & Ramirez, T. (2023). Early Relational Health: A Review of Research, Principles, and Perspectives. The Burke Foundation. https://nurtureconnection.org/resource/early-relational-health-principles/
96 Weihrauch, L., Schäfer, R., & Franz, M. (2014). Long-term efficacy of an attachment-based parental training program for single mothers and their children: A randomized controlled trial. Journal of Public Health, 22(2), 139–153. 10.1007/s10389-013-0605-4
97 Paulson, J. F., & Bazemore, S. D. (2010). Prenatal and postpartum depression in fathers and its association with maternal depression: a meta-analysis. JAMA, 303(19), 1961–1969. 10.1001/jama.2010.605 20483973
98 Cameron, E. E., Sedov, I. D., & Tomfohr-Madsen, L. M. (2016). Prevalence of paternal depression in pregnancy and the postpartum: An updated meta-analysis. Journal of affective disorders, 206, 189–203. 10.1016/j.jad.2016.07.044 27475890
99 Rao, W. W., Zhu, X. M., Zong, Q. Q., Zhang, Q., Hall, B. J., Ungvari, G. S., & Xiang, Y. T. (2020). Prevalence of prenatal and postpartum depression in fathers: A comprehensive meta-analysis of observational surveys. Journal of affective disorders, 263, 491–499. 10.1016/j.jad.2019.10.030 31757623
100 Leach, L. S., Poyser, C., Cooklin, A. R., & Giallo, R. (2016). Prevalence and course of anxiety disorders (and symptom levels) in men across the perinatal period: A systematic review. Journal of affective disorders, 190, 675–686. 10.1016/j.jad.2015.09.063 26590515
101 Leiferman, J. A., Farewell, C. V., Jewell, J., Rachael Lacy, Walls, J., Harnke, B., & Paulson, J. F. (2021). Anxiety among fathers during the prenatal and postpartum period: a meta-analysis. Journal of psychosomatic obstetrics and gynaecology, 42(2), 152–161. 10.1080/0167482X.2021.1885025 33632067
102 Garfield, C. F., Duncan, G., Rutsohn, J., McDade, T. W., Adam, E. K., Coley, R. L., & Chase-Lansdale, P. L. (2014). A longitudinal study of paternal mental health during transition to fatherhood as young adults. Pediatrics, 133(5), 836–843. 10.1542/peds.2013-3262 24733877
103 American Academy of Pediatrics. (n.d.). Types of Families. HealthyChildren.org. https://www.healthychildren.org/English/family-life/family-dynamics/types-of-families/
104 Strizzi, J. M., Ciprić, A., Sander, S., & Hald, G. M. (2021). Divorce is stressful, but how stressful? Perceived stress among recently divorced Danes. Journal of Divorce & Remarriage, 62(4), 295–311. 10.1080/10502556.2021.1871838
105 Generations United. (2023). 2023 State of Grandfamilies Report: Building Resilience: Supporting Grandfamilies’ Mental Health and Wellness. https://www.gu.org/resources/building-resilience-grandfamilies-mental-health-and-wellness/
106 Dolbin-MacNab, M. L., & O’Connell, L. M. (2021). Grandfamilies and the Opioid Epidemic: A Systemic Perspective and Future Priorities. Clinical child and family psychology review, 24(2), 207–223. 10.1007/s10567-021-00343-7 33491118
107 Brown, C. C., Adams, C. E., George, K. E., & Moore, J. E. (2021). Mental Health Conditions Increase Severe Maternal Morbidity By 50 Percent And Cost $102 Million Yearly In The United States. Health affairs (Project Hope), 40(10), 1575–1584. 10.1377/hlthaff.2021.00759 34606352
108 Luca, D. L., Margiotta, C., Staatz, C., Garlow, E., Christensen, A., & Zivin, K. (2020). Financial Toll of Untreated Perinatal Mood and Anxiety Disorders Among 2017 Births in the United States. American journal of public health, 110(6), 888–896. 10.2105/AJPH.2020.305619 32298167
109 Felitti, V. J., Anda, R. F., Nordenberg, D., Williamson, D. F., Spitz, A. M., Edwards, V., Koss, M. P., & Marks, J. S. (1998). Relationship of childhood abuse and household dysfunction to many of the leading causes of death in adults. The Adverse Childhood Experiences (ACE) Study. American journal of preventive medicine, 14(4), 245–258. 10.1016/s0749-3797(98)00017-8 9635069
110 Merrick, M. T., Ford, D. C., Ports, K. A., Guinn, A. S., Chen, J., Klevens, J., Metzler, M., Jones, C. M., Simon, T. R., Daniel, V. M., Ottley, P., & Mercy, J. A. (2019). Vital Signs: Estimated Proportion of Adult Health Problems Attributable to Adverse Childhood Experiences and Implications for Prevention - 25 States, 2015-2017. MMWR. Morbidity and mortality weekly report, 68(44), 999–1005. 10.15585/mmwr.mm6844e1 31697656
111 Mamun, A., Biswas, T., Scott, J., Sly, P. D., McIntyre, H. D., Thorpe, K., Boyle, F. M., Dekker, M. N., Doi, S., Mitchell, M., McNeil, K., Kothari, A., Hardiman, L., & Callaway, L. K. (2023). Adverse childhood experiences, the risk of pregnancy complications and adverse pregnancy outcomes: a systematic review and meta-analysis. BMJ open, 13(8), e063826. 10.1136/bmjopen-2022-063826
112 Hughes, K., Bellis, M. A., Hardcastle, K. A., Sethi, D., Butchart, A., Mikton, C., Jones, L., & Dunne, M. P. (2017). The effect of multiple adverse childhood experiences on health: a systematic review and meta-analysis. The Lancet Public health, 2(8), e356–e366. 10.1016/S2468-2667(17)30118-4 29253477
113 Goodman, S. H., & Gotlib, I. H. (1999). Risk for psychopathology in the children of depressed mothers: a developmental model for understanding mechanisms of transmission. Psychological review, 106(3), 458–490. 10.1037/0033-295x.106.3.458 10467895
114 National Research Council (US) and Institute of Medicine (US) Committee on Depression, Parenting Practices, and the Healthy Development of Children; England MJ, Sim LJ, editors. (2009). Depression in Parents, Parenting, and Children: Opportunities to Improve Identification, Treatment, and Prevention. National Academies Press (US). https://www.ncbi.nlm.nih.gov/books/NBK215128/
115 Beardslee, W. R., Keller, M. B., Seifer, R., Lavori, P. W., Staley, J., Podorefsky, D., & Shera, D. (1996). Prediction of adolescent affective disorder: effects of prior parental affective disorders and child psychopathology. Journal of the American Academy of Child and Adolescent Psychiatry, 35(3), 279–288. 10.1097/00004583-199603000-00008 8714315
116 Stracke, M., Heinzl, M., Müller, A. D., Gilbert, K., Thorup, A. A. E., Paul, J. L., & Christiansen, H. (2023). Mental Health Is a Family Affair-Systematic Review and Meta-Analysis on the Associations between Mental Health Problems in Parents and Children during the COVID-19 Pandemic. International journal of environmental research and public health, 20(5), 4485. 10.3390/ijerph20054485 36901492
117 Uher, R., Pavlova, B., Radua, J., Provenzani, U., Najafi, S., Fortea, L., Ortuño, M., Nazarova, A., Perroud, N., Palaniyappan, L., Domschke, K., Cortese, S., Arnold, P. D., Austin, J. C., Vanyukov, M. M., Weissman, M. M., Young, A. H., Hillegers, M. H. J., Danese, A., Nordentoft, M., … Fusar-Poli, P. (2023). Transdiagnostic risk of mental disorders in offspring of affected parents: a meta-analysis of family high-risk and registry studies. World psychiatry : official journal of the World Psychiatric Association (WPA), 22(3), 433–448. 10.1002/wps.21147 37713573
118 Wolicki, S. B., Bitsko, R. H., Cree, R. A., Danielson, M. L., Ko, J. Y., Warner, L., & Robinson, L. R. (2021). Mental Health of Parents and Primary Caregivers by Sex and Associated Child Health Indicators. Adversity and resilience science, 2(2), 125–139. 10.1007/s42844-021-00037-7 36523952
119 Hay, D. F., Pawlby, S., Sharp, D., Asten, P., Mills, A., & Kumar, R. (2001). Intellectual problems shown by 11-year-old children whose mothers had postnatal depression. Journal of child psychology and psychiatry, and allied disciplines, 42(7), 871–889. 10.1111/1469-7610.00784 11693583
120 Smith, M. (2004). Parental mental health: Disruptions to parenting and outcomes for children. Child & Family Social Work, 9(1), 3–11. 10.1111/j.1365-2206.2004.00312.x
121 Meadows, S. O., McLanahan, S. S., & Brooks-Gunn, J. (2007). Parental depression and anxiety and early childhood behavior problems across family types. Journal of Marriage and Family, 69(5), 1162–1177. 10.1111/j.1741-3737.2007.00439.x
122 Monk, C., Lugo-Candelas, C., & Trumpff, C. (2019). Prenatal Developmental Origins of Future Psychopathology: Mechanisms and Pathways. Annual review of clinical psychology, 15, 317–344. 10.1146/annurev-clinpsy-050718-095539
123 Fisher S. D. (2016). Paternal Mental Health: Why Is It Relevant?. American journal of lifestyle medicine, 11(3), 200–211. 10.1177/1559827616629895 30202331
124 Low, J., Bishop, A., & Pilkington, P. D. (2022). The longitudinal effects of paternal perinatal depression on internalizing symptoms and externalizing behavior of their children: A systematic review and meta-analysis. Mental Health & Prevention, 26, 200230. https://www.sciencedirect.com/science/article/abs/pii/S2212657022000022?via%3Dihub
125 Kahn, R. S., Brandt, D., & Whitaker, R. C. (2004). Combined effect of mothers’ and fathers’ mental health symptoms on children’s behavioral and emotional well-being. Archives of pediatrics & adolescent medicine, 158(8), 721–729. 10.1001/archpedi.158.8.721 15289242
126 Kamis, C. (2021). The Long-Term Impact of Parental Mental Health on Children’s Distress Trajectories in Adulthood. Society and Mental Health, 11(1), 54–68. 10.1177/2156869320912520 34094696
127 Office of Justice Programs. (n.d.). Roadmap to Reentry: Reducing Recidivism Through Reentry Reforms at the Federal Bureau of Prisons. Washington, DC: U.S. Department of Justice, Federal Bureau of Prisons. https://www.justice.gov/reentry/file/844421/dl
128 Department of Justice Archives. (2023, November 29). Prison Reform: Reducing Recidivism by Strengthening the Federal Bureau of Prisons. U.S. Department of Justice: Federal Bureau of Prisons. https://www.justice.gov/archives/prison-reform
129 Ray, T. K., & Pana-Cryan, R. (2021). Work Flexibility and Work-Related Well-Being. International journal of environmental research and public health, 18(6), 3254. 10.3390/ijerph18063254 33801122
130 Office of the Surgeon General (OSG). (2022). The U.S. Surgeon General’s Framework for Workplace Mental Health & Well-Being. US Department of Health and Human Services. https://www.hhs.gov/sites/default/files/workplace-mental-health-well-being.pdf
131 Coombs, N. C., Meriwether, W. E., Caringi, J., & Newcomer, S. R. (2021). Barriers to healthcare access among U.S. adults with mental health challenges: A population-based study. SSM - population health, 15, 100847. 10.1016/j.ssmph.2021.100847 34179332
132 de Oliveira, C., Saka, M., Bone, L., & Jacobs, R. (2023). The Role of Mental Health on Workplace Productivity: A Critical Review of the Literature. Applied health economics and health policy, 21(2), 167–193. 10.1007/s40258-022-00761-w 36376610
133 Goetzel, R. Z., Roemer, E. C., Holingue, C., Fallin, M. D., McCleary, K., Eaton, W., Agnew, J., Azocar, F., Ballard, D., Bartlett, J., Braga, M., Conway, H., Crighton, K. A., Frank, R., Jinnett, K., Keller-Greene, D., Rauch, S. M., Safeer, R., Saporito, D., Schill, A., & Mattingly, C. R. (2018). Mental Health in the Workplace: A Call to Action Proceedings From the Mental Health in the Workplace-Public Health Summit. Journal of occupational and environmental medicine, 60(4), 322–330. 10.1097/JOM.0000000000001271 29280775
134 American Psychiatric Association. (2024, March). Stigma, Prejudice and Discrimination Against People with Mental Illness. https://www.psychiatry.org/patients-families/stigma-and-discrimination
135 Office of Minority Health. (n.d.). Think Cultural Health. U.S. Department of Health and Human Services. https://thinkculturalhealth.hhs.gov/
136 Cohen, S., & Wills, T. A. (1985). Stress, social support, and the buffering hypothesis. Psychological bulletin, 98(2), 310–357.3901065
137 Southwick, S. M., Sippel, L., Krystal, J., Charney, D., Mayes, L., & Pietrzak, R. (2016). Why are some individuals more resilient than others: the role of social support. World psychiatry : official journal of the World Psychiatric Association (WPA), 15(1), 77–79. 10.1002/wps.20282 26833614
138 Gennetian LA, Marti M, Kennedy JL, Kim JH, Duch H. (2019). Supporting parent engagement in a school readiness program: Experimental evidence applying insights from behavioral economics. Journal of Applied Developmental Psychology, 62:1–10. 10.1016/j.appdev.2018.12.006
139 Ascend, The Aspen Institute. (2020). Principles for Engaging and Centering Parent Voice. https://ascend.aspeninstitute.org/resources/principles-for-engaging-and-centering-parent-voice/
140 U.S. Department of Health and Human Services. (2024). Strategies and Recommendations for Supporting Mental Health. https://eclkc.ohs.acf.hhs.gov/policy/im/acf-ohs-im-24-01
141 National Education Association. (n.d.). What are Community Schools?. https://www.nea.org/student-success/great-public-schools/community-schools/what-are-they
142 Ascend at The Aspen Institute and The JED Foundation. (2021, May). Improving Mental Health of Student Parents: A Framework for Higher Education. https://ascend.aspeninstitute.org/wp-content/uploads/2021/05/MentalHealthFramework_Final.pdf
143 Substance Abuse and Mental Health Services Administration (SAMHSA). (2024). Practical Guide for Implementing a Trauma-Informed Approach. https://www.samhsa.gov/resource/ebp/practical-guide-implementing-trauma-informed-approach
144 Ascend at the Aspen Institute. (2024, March). Portfolio of Trauma-Informed Tools for 2Gen Approaches. https://ascend.aspeninstitute.org/wp-content/uploads/2024/03/Ascend_Trauma-Informed-Care-Toolkit_05.2024.pdf
145 American Academy of Pediatrics. (2024, May 20). Recommendations for Preventive Pediatric Health Care. https://downloads.aap.org/AAP/PDF/periodicity_schedule.pdf
146 The White House. (2023). U.S. National Plan to End Gender-Based Violence: Strategies for Action. https://www.whitehouse.gov/wp-content/uploads/2023/05/National-Plan-to-End-GBV.pdf
147 Gov.UK Office for Health Improvement & Disparities. (2022, January 27). Guidance: Social Prescribing: Applying All Our Health. https://www.gov.uk/government/publications/social-prescribing-applying-all-our-health/social-prescribing-applying-all-our-health
148 National Academy for Social Prescribing. (2024, June 6). Social Prescribing Around the World. https://socialprescribingacademy.org.uk/media/4lbdy5ip/social-prescribing-around-the-world.pdf
149 Coleman, C. L., Morrison, M., Perkins, S. K., Brosco, J. P., & Schor, E. L. (2022). Quality of Life and Well-Being for Children and Youth with Special Health Care Needs and their Families: A Vision for the Future. Pediatrics, 149(Suppl 7), e2021056150G. 10.1542/peds.2021-056150G
150 National Council for Mental Wellbeing, Center of Excellence for Integrated Health Solutions. (n.d.) Resources. https://www.thenationalcouncil.org/program/center-of-excellence/resources
151 Laderman, M., & Mate, K. S. (2016). Behavioral Health Integration in Acute Medical Settings: An Opportunity to Improve Outcomes and Reduce Costs. Joint Commission journal on quality and patient safety, 42(7), 331–336. 10.1016/s1553-7250(16)42046-5 27301838
152 Weissman M. M. (2020). Big Data Begin in Psychiatry. JAMA psychiatry, 77(9), 967–973. 10.1001/jamapsychiatry.2020.0954 32401285
153 Mosle, A. & Sims, M. (2024). Building Evidence Together for a Better Tomorrow. Ascend at the Aspen Institute. https://ascend.aspeninstitute.org/resources/building-evidence-together-for-a-better-tomorrow/
154 Substance Abuse and Mental Health Services Administration (SAMHSA). (n.d.). Family, Parent and Caregiver Peer Support in Behavioral Health. U.S. Department of Health and Human Services. https://www.samhsa.gov/sites/default/files/programs_campaigns/brss_tacs/family-parent-caregiver-support-behavioral-health-2017.pdf
155 UNICEF. (n.d.). How to reduce stress. https://www.unicef.org/parenting/mental-health/how-reduce-stress-parents
156 Substance Abuse and Mental Health Services Administration (SAMHSA). (n.d.). What is Mental Health?. U.S. Department of Health and Human Services. https://www.samhsa.gov/mental-health
157 Administration for Children and Families. (n.d.). Parents and Caregivers. U.S. Department of Health and Human Services. https://www.acf.hhs.gov/ecd/parents-and-caregivers