# Background

There are approximately 63 million parents living with children under the age of 18 in the U.S.^4^ There are also millions of non-parent caregivers who carry the primary responsibility for caring for children.^5,^ ^6^ Parents and caregivers play a critical role in providing the formative safe, stable, and nurturing relationships and environments that children need in order to thrive.

The experience of raising a child can produce a range of emotions for a parent or caregiver.^7^ It can bring a sense of meaning and purpose along with experiences of joy, love, and human connection. It can also involve daunting challenges and significant, sometimes relentless, stress. When severe or prolonged, stress can increase the likelihood of mental health challenges.^8,^ ^9,^ ^10^ In turn, the mental health of parents and caregivers can have profound impacts on the well-being of children, families, and society. Studies point to a complex interplay of bidirectional effects where parental mental health can influence child outcomes, and vice versa.^11,^ ^12,^ ^13,^ ^14^

This Advisory recognizes the critical role of parents and caregivers in our society and the importance of both reducing their stress and protecting their mental health and well-being. It explores the unique stressors that parents and caregivers face; the impact of these stressors on the mental health and well-being of parents, caregivers, and children; and the policies, programs, and cultural shifts we need to make to allow parents and caregivers to flourish and thrive.