# Key Terms

## Parents and Caregivers

The definition of a parent or caregiver varies across different research studies cited in this document. In making conclusions and recommendations, this document regards a parent or a caregiver as an individual providing caretaking for a child under the age of 18 (inclusive of biological, step, adoptive, kinship, and other types of caregivers).

## Children

This document refers to a child as an individual who is under the age of 18 years old. Terms utilized to describe this population such as children, youth, and young people may be used interchangeably in this document and across different research studies cited.

## Stress

A state of worry or mental tension caused by a difficult situation.^1^ Stressors can be internal (e.g., unrealistic expectations, self-doubt) or external (e.g., work pressure, financial hardship, family problems or disruptions) and may exacerbate existing mental health conditions or challenges, leading to increased symptoms or difficulties in coping.

## Mental Health Conditions

(also referred to as Mental Illnesses or Mental Health Disorders)

Diagnosable disorders that significantly impact an individual’s thinking, mood, and/or behavior. They are typically characterized by specific symptoms and criteria and may be episodic or chronic in nature.^2^ Examples include, but are not limited to depressive disorders, anxiety disorders, trauma and stress-related disorders, bipolar disorders, schizophrenia spectrum disorders, and personality disorders.^3^ Mental health challenges refer to experiences or difficulties individuals may face, which can affect their mental health without necessarily meeting the criteria for a diagnosable mental health condition.