# Dedication

This Surgeon General’s Advisory is dedicated to the millions of parents and caregivers across America whose steadfast dedication and compassion continues to nurture the bodies, minds, and spirits of our nation’s children.

The Office of the Surgeon General would like to recognize our parents and caregivers whose selfless sacrifices and unconditional love made us the people we are. The opportunity to work on this Advisory and to serve our nation would not have been possible without you.

- Angela & Joseph
- Anne, Lillian & Paul
- Aretha, Rose Marie & Winston
- Ashok & Rajni
- Atul & Mohana
- Bong Nam & Sung Taek
- Britt & Dan
- Butch, Kathy & Katie
- Chaia & Peter
- Cindy, Ross & Stacey
- Dan & Naomi
- Debbie & Steven
- Elsa, Pedro & Sonia
- Emeka & Susan
- Frank & Robin
- Hallegere Murthy & Myetraie
- Harriet & Steve
- Hattie & Virginia
- Izaak, Lisa & Martin
- Jerome & Paitoon
- Jill & William
- Johann & Miya
- Kara & Paul
- Karimeh
- Lloyd & Ruth
- Luise & Michael
- Matthew & Wendy
- Michael & Susan
- Pamela Kyle
- Rafael & Valdery
- Rama & Srinivasa
- Robert & Shelley
- Sylvia