# 3 The Impact of Parental Mental Health

Parental mental health conditions can have far-reaching and profound implications for children, families as a whole, and for society, including increased health care costs and reduced economic productivity.^107,^ ^108^

Parental mental health can influence the emotional climate, responsiveness, and consistency of caregiving at home, all of which are crucial for a child’s emotional and cognitive development. Living with a household member, such as a parent or caregiver, with a mental health condition or substance misuse are among the originally studied adverse childhood experiences (ACEs).^109^ ACEs are linked to worse mental, physical, and behavioral health outcomes across the lifespan of a child.^110,^ ^111,^ ^112^ Importantly, how a parent’s or caregiver’s mental health affects their behavior and functioning (e.g., does it change the amount or frequency of caregiving provided) is a critical factor in determining how it impacts a child.^113,^ ^114^ On the other hand, an adult’s mental health challenges may not have a negative impact on a child if they do not disrupt the child’s sense of safety, stability, support, and bonding with parents or caregivers.

Children of parents with mental health conditions may face heightened risks, including for symptoms of depression and anxiety and for earlier onset, recurrence, and prolonged functional impairment from mental health conditions.^114,^ ^115,^ ^116,^ ^117^ [underlined: One study found that children of a primary caregiver who reported poor mental health were four times more likely to have poor general health (5.1% vs 1.3%) and two times more likely to have mental, behavioral, or developmental disorders (41.8% vs 21.0%).]^118^ Additionally, these children are prone to cognitive, academic, and interpersonal struggles.^114,^ ^119,^ ^120^

Both maternal and paternal mental health conditions are shown to impact the well-being of children. Maternal mental health conditions have been found to significantly impact a child’s well-being and environment and can serve as a critical determinant of child outcomes.^121,^ ^122^ For example, research indicates that maternal distress—defined broadly to include perceived stress, life events, depression, and anxiety—during the prenatal period is associated with a child’s future increased risk for mental health conditions.^122^ Paternal mental health conditions are less well studied, but research indicates they can also significantly influence child health and development, with perinatal depression in fathers linked to increased internalizing (e.g., sadness, anxiety, and depression) and externalizing symptoms (e.g., aggression, irritability, and destructive behaviors) among children.^123,^ ^124^ Having both parents affected by mental health conditions can be particularly distressing for children, but having at least one non-affected parent can mitigate the effects.^121,^ ^125,^ ^126^

[underlined: The mental health conditions of parents can pose greater risks for children when combined with additional risk factors like poverty, exposure to violence, and marital conflict, but they can be mitigated by protective factors like social support networks and positive parenting behaviors as well.]^114^ Thus, addressing parental mental health conditions, and importantly the underlying stressors and causes, is critical for the well-being of children and society.

[image]

Both maternal and paternal mental health conditions are shown to impact the well-being of children.