# 2 The Relationship Between Parental Stress & Mental Health

Chronic or excessive stress, coupled with other complex environmental and biological factors, can increase the risk of mental health conditions for individuals.

Environmental factors can include exposure to alcohol or drugs, discrimination and racism, and adverse childhood experiences (ACEs) such as abuse, neglect, and trauma including the loss of a loved one.^d,^ ^59,^ ^60,^ ^61,^ ^62^ Biological factors can include neurochemical factors influenced by genetics, epigenetics, and hormonal fluctuations associated with pregnancy and the perinatal period.^62,^ ^63,^ ^64,^ ^65,^ ^66,^ ^67,^ ^68^ Individual-level variation in one’s ability to cope with stress also plays a role in the predisposition to mental health conditions.^69^ [underlined: Recent data from 2021-2022 indicate that among parents, 23.9% (or 20.3 million) had any mental illness and 5.7% (or 4.8 million) of parents had a serious mental illness.]^70^ Additionally, certain parents and caregivers experience a disproportionate level of mental health conditions (Box 2). Further, the mental health conditions experienced by parents can manifest differently based on the gender of the parent and the family structure, among other factors, as described below. Understanding how different populations are affected is vital for tailoring effective interventions and support.

BOX 2 Disproportionate Mental Health Conditions Among Certain Parents and Caregivers

Mental health conditions disproportionately affect certain groups of parents,^29,^ ^71,^ ^72,^ ^73,^ ^74,^ ^75,^ ^76,^ ^77^ reflecting broader social determinants of health. Circumstances like family or community violence, poverty, and racism and discrimination, among other circumstances, can increase the risk for mental health conditions.^2,^ ^78,^ ^79,^ ^80,^ ^81^ Particular consideration should be given to parents and caregivers who live in low-income households, experience job instability or unemployment, are racial and ethnic minorities, are sexual and gender minorities, are immigrants, are parents and caregivers of undocumented children, are exposed to violence (e.g., intimate partner violence), are incarcerated, experience food insecurity, are divorced, are in the military or deployed, have disabilities or experience chronic medical problems or trauma, and who have intersectional identities, among others. For example, one study found that a father’s recent incarceration increased the mother’s risk of experiencing major depressive symptoms and life dissatisfaction even after economic well-being and family functioning were controlled for.^82^

## Maternal Mental Health

Women generally have a higher prevalence of mental health conditions than men.^83^ For women, the perinatal period is particularly important. Postpartum depressive symptoms affect approximately 1-in-8 mothers, with a disproportionate impact on women of color,^84,^ ^85^ and can occur anytime in the first year after giving birth.^86^ [underlined: In fact, the leading cause of pregnancy-related deaths is mental health conditions (22.7%), including from suicides and overdose/poisoning related to substance use disorders.]^87^ Past history of a mental health condition, the experience of racism and discrimination, poor social support, and extreme or traumatic stress, among other factors, can contribute to vulnerability during this period.^88,^ ^89,^ ^90^ Another critical period for maternal mental health is a child’s early years. Nurturing relationships and secure attachments during this period are pivotal to fostering positive outcomes for both mother and child.^91,^ ^92,^ ^93,^ ^94,^ ^95,^ ^96^

## Paternal Mental Health

In comparison to mothers, mental health conditions among fathers have been understudied. The most extensive research has focused on perinatal depression, which may occur in approximately 8-14% of men between the first trimester of a partner’s pregnancy and the end of the first year postpartum.^97,^ ^98,^ ^99^ [underlined: Further, paternal perinatal anxiety may occur in approximately 2-18% of men.]^100,^ ^101^ Additionally, a 23-year longitudinal study found that fathers living in the home had increasing depressive symptoms during their children’s first five years of life.^102^

## The Role of Family Structure

Recognizing and understanding family structures,^103^ including single-parent families, blended families, kinship families,^e^ foster parent families, cohabiting partner families, same-sex and non-binary parent families, and multi-generational households, among others, is important as each involves unique dynamics that can present both opportunities and challenges for parents’ and caregivers’ mental health and well-being.

For example, LGBTQ-parent families may face challenges such as discrimination and societal stigma that could exacerbate their stress and mental health challenges. Single parents may face heightened stressors due to sole caregiving responsibilities, financial strain, and lack of support, which could negatively impact parents’ mental health and well-being. Conversely, multigenerational households that provide shared caregiving responsibilities and helpful social support networks could benefit parents’ mental health by reducing stress and providing emotional support.

In situations of acute family disruption, such as, but not limited to, experiencing divorce, separation, cohabitation dissolution (e.g., due to intimate partner violence), parental incarceration, involvement with child welfare services, or separation due to immigration policies, the stressors and challenges experienced by parents, caregivers, and families can be exacerbated. For example, research suggests that recent divorcees have significantly higher perceived stress levels than both the general population and those who have been divorced or separated for a longer period of time.^104^

Lastly, many other caregivers assume primary caregiving responsibility when parents cannot, thus acting as a critical safety net for children. [underlined: In recent years, there has been a notable increase in such individuals taking on caregiving responsibilities for children, with approximately 2.4 million children being raised by grandparents, other relatives, or family friends, without their biological parent(s) in the household.]^5,^ ^105^ Despite the crucial role of these caregivers, they can experience difficulties in navigating service systems and dissatisfaction with the amount or type of services available to them.^6,^ ^105,^ ^106^

[image]

Recognizing and understanding family structures,^103^ […] is important as each involves unique dynamics that can present both opportunities and challenges for parents’ and caregivers’ mental health and well-being.

d Trauma is defined as exposure to an event or a circumstance that is physically or emotionally harmful or life-threatening, with lasting adverse effects on the individual’s mental, physical, social, emotional, and/or spiritual well-being. (SAMHSA, 2024) Source: Substance Abuse and Mental Health Services Administration (SAMHSA). (2024, May 29). Trauma and violence. https://www.samhsa.gov/trauma-violence

e A kinship family forms when a relative or close family friend becomes a child’s primary caregiver. (NIA, 2023) Source: National Institutes of Health, National Institute on Aging (NIA). (2023, July 6). Grandfamilies and Kinship Families: Caring for Young Relatives. https://www.nia.nih.gov/health/caregiving/grandfamilies-and-kinship-families-caring-young-relatives