# Acknowledgments

We are grateful to all of the experts, academic researchers, associations, and community-based organizations across the country who shared their insights to inform this Advisory.

The U.S. Surgeon General’s Advisory on the Mental Health & Well-Being of Parents was prepared by the Office of the Surgeon General with valuable contributions from partners across the U.S. Government, including but not limited to:

- Administration for Children and Families (ACF)
- Administration for Community Living (ACL)
- Centers for Disease Control and Prevention (CDC)
- Centers for Medicaid & Medicare Services (CMS)
- Food and Drug Administration (FDA)
- Health Resources and Services Administration (HRSA)
- National Institutes of Health (NIH)
- Office of the Assistant Secretary for Health (OASH)
- Office on Women’s Health (OWH)
- Substance Abuse and Mental Health Services Administration (SAMHSA)