# Vision and Goals

## The Vision

of the Call To Action is

To advance the general health and well-being of all Americans by creating critical partnerships at all levels of society to engage in programs to promote oral health and prevent disease.

## The Goals

of the Call To Action reflect those of Healthy People 2010:

To promote oral health.

To improve quality of life.

To eliminate oral health disparities.

As a force for change to enhance the nation’s overall health and well-being, the Call To Action urges that oral health promotion, disease prevention, and oral health care have a presence in all health policy agendas set at local, state, and national levels. For this to happen, the public, health professionals, and policymakers must understand that oral health is essential to general health and well-being at every stage of life. In addition, the oral health community must be ready to act in efforts to address the nation’s overall health agenda.