# References

1 U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. Rockville, MD: U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health, 2000:2-3. (http://www.nidcr.nih.gov/)
2 U.S. Department of Health and Human Services. Healthy People 2010. 2nd ed. 2 vols. Washington, DC: U.S. Government Printing Office, November 2000. (http://www.healthypeople.gov/)
3 Interventions to Prevent Dental Caries, Oral and Pharyngeal Cancers, and Sports-related Craniofacial In- juries: Systematic Reviews of Evidence, Recommendations from the U.S. Task Force on Community Preventive Services, and Expert Commentary. Am J Prev Med 2002; 1-84; 23(1S)
4 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd Edition, Williams and Wilkins, Baltimore. 1996; 953p.
5 Brown LJ, Lazar V. Minority dentists: why do we need them? Closing the gap. Washington Office of Minority Health, U.S. Department of Health and Human Services; 1999 Jul. p.6-7.