# Next Steps

This National Call To Action To Promote Oral Health provides the basis for integrating efforts of current and future members of the Partnership Network to facilitate improvement of the nation’s health through oral health activities. The five actions outlined in this report require public-private partnerships at all levels of society and a commitment from those who are involved in health programs to contribute expertise and resources. The Partnership Network members will serve to foster communication and collaborations and will act as a forum to measure progress toward these actions in coordination with the Healthy People 2010 initiative.