# Partnership Network Members (as of November 2001)

- Academy of General Dentistry
- American Academy of Pediatrics
- American Academy of Pediatric Dentistry
- American Association of Public Health Dentistry
- American Association of Women Dentists
- American College of Nurse-Midwives
- American Dental Association
- American Dental Hygienists’ Association
- American Dental Trade Association
- American Dental Education Association
- American Medical Association
- American Public Health Association
- American Society of Dentistry for Children
- Association of Maternal and Child Health Programs
- Association of Academic Health Centers
- Association of Clinicians for the Underserved
- Association of Maternal and Child Health Programs
- Association of Schools of Public Health
- Association of State and Territorial Health Officials
- Association of State and Territorial Dental Directors
- Bureau of Dental Health, New York State Health Department
- Campbell Hoffman Foundation
- Center for Child Health Research
- Children’s Defense Fund
- Children’s Dental Health Project
- Colorado Department of Public Health and Environment Oral Health Program
- Connecticut Health Foundation
- Consumer Health Care Products Association
- Delta Dental Plans Association
- Delta Dental/Washington Dental Service
- DENTSPLY InternationalFamilies USA
- Family Voices (Federation for Children with Special Needs)
- Friends of NIDCR
- Colgate Palmolive Company
- Grantmakers In Health
- Henry Schein, Inc.
- Hispanic Dental Association
- Illinois Department of Public Health
- International Association for Dental Research, American Association for Dental Research
- Maryland Department of Health and Mental Hygiene
- National Oral Health Policy Center
- Minority Health Communications
- National Association of Child Advocates
- National Association of Children’s Hospitals
- National Association of Community Health Centers
- National Association of County and City Health Officials
- National Association of Local Boards of Health
- National Association of State Medicaid Directors
- National Maternal and Child Oral Health Resource Center
- National Conference of State Legislatures
- National Dental Association
- National Foundation for Ectodermal Dysplasias
- National Governors’ Association
- National Health Law Program
- National Health Policy Forum
- National Association of Urban-Based HMOs
- New York State Department of Health
- Oral Health America
- Reforming States Group
- Research America
- Ronald McDonald House Charities
- Special Olympics and Special Olympics University
- The Children’s National Medical Center
- The Robert Wood Johnson Foundation
- The Rotunda
- Urban Institute Health Policy Center
- Washington Dental Service Foundation
- W.K. Kellogg Foundation
- Women’s and Children’s Health Policy Center