# Strategic Direction 3: Treatment and Support Services

Individuals at high risk for suicide require clinical evaluation and care to identify and treat mental health and medical conditions, and to specifically address suicide risk. In the past, it was believed that appropriately treating underlying conditions (e.g., mood disorders, substance abuse) would remove the risk for suicide. However, this is not always the case. A growing body of evidence suggests that suicide prevention is enhanced when specific treatments for underlying conditions are combined with strategies that directly address suicide risk.

Evidence-based and promising approaches for caring for high-risk patients include safety planning (i.e., working collaboratively with each patient to develop an action plan for times of crises) and specific forms of psychotherapy that can be used to support treatment for underlying mental health conditions. Addressing suicide risk may be particularly important when treating individuals who have survived a suicide attempt. There is now substantial evidence that interventions such as dialectical behavior therapy (DBT) and cognitive behavior therapy for suicide prevention (CBT-SP) can help reduce suicidal behaviors among these patients. In addition, clozapine has been found to be effective in reducing suicidal behaviors among patients with schizophrenia86 and lithium shows promise in patients with mood disorders.87

Principles that should guide care for individuals with high suicide risk include the following:

■ Provision of evidence-based treatment as soon as possible after suicide risk is identified;
■ Person- and relationship-centered care, which includes improving patient-provider communication, involving individuals with suicide risk in the development of safety plans, and providing care that is matched to the person’s level of risk, needs, and preferences;
■ Culturally competent care that addresses the needs of diverse groups of patients, including linguistic, racial/ethnic, sexual, and gender minorities;
■ Multiple points of access to appropriate treatment and a focus on providing support in the least restrictive environment;
■ Integration of care across various systems and settings (via several possible models, from communication and collaboration to full integration) and shared reporting of client outcomes;
■ Continuity of care for individuals with suicide risk with a particular focus on immediate (if possible, within 48 hours) and continuous followup after a suicide attempt following discharge from a hospital, ED, or other inpatient facility;
■ Appropriate empowerment of families and significant others in treatment, peer support, and post-discharge followup;
■ Use of systems-level strategies, such as establishing the organizational goal of eliminating deaths by suicide, tracking and investigating suicide deaths, and using other continuous quality improvement efforts; and
■ Recovery-oriented services that are based on the following understanding: recovery emerges from hope, is person-driven, occurs through many pathways, is holistic, is supported by peers and allies, is supported through relationships and social networks, is culturally based, is grounded in respect, is supported by addressing trauma, and involves the individual, family, and community.88

## Goal 8 Promote suicide prevention as a core component of health care services

The use of comprehensive, systems-level strategies that make suicide prevention a core goal has been shown to improve outcomes for patients with suicide risk. A 2011 report by the Clinical Care and Intervention Task Force of the Action Alliance identified several of these programs.89 Of these interventions, the most thoroughly researched is the U.S. Air Force Suicide Prevention Program, which has been found to reduce death by suicide by one-third.16

The integration of suicide prevention into the delivery of mental health services has also been found to help prevent suicides in the United Kingdom. A study that examined data from 91 mental health service organizations in England and Wales found that the implementation of key suicide prevention recommendations was associated with a reduction in suicide rates among patients. 50 Providing 24-hour crisis care was associated with the greatest reduction in suicide rates. Other recommendations included: assertive, proactive outreach; followup within 7 days of inpatient discharge; training of clinical staff in the management of suicide risk every 3 years; a dual diagnosis policy for those with both mental disorders and substance abuse; and multidisciplinary review and information sharing with families following a suicide.

VA and its health system, the Veteran’s Health Administration (VHA), also have adopted a comprehensive approach in which suicide prevention is a core component of mental health and substance abuse services. As part of this approach, a suicide prevention coordinator is placed at every VA medical center in the country. Preliminary data suggest that the implementation of these programs has been associated with a reduction in suicide among important high-risk subgroups of those receiving health care through the VHA, including men in midlife.90, 91

Other programs that have garnered attention for their comprehensive approaches and that report promising preliminary data include the Henry Ford Health System’s (HFHS) “Perfect Depression Care”49 and the Central Arizona Programmatic Suicide Deterrent Project.89 Although more research is needed, initial findings suggest that progress can be made when health systems or other organizations focus on making suicide prevention a core priority by obtaining leadership support, changing the organizational culture around suicide prevention, and engaging each component of a system to assume its legitimate role in suicide prevention.

While providers of mental health and substance abuse services have a special responsibility for addressing suicide risk, suicide prevention should not be viewed as an area of specialization that applies only to these professionals or to a single setting, such as inpatient psychiatry. Suicide prevention requires the active engagement of health and social services, as well as the coordination of care across multiple settings, thereby ensuring continuity of care and promoting patient safety. Services addressing mental and substance use disorders, as well as suicide prevention, can be provided in numerous settings, including crisis centers, health centers, clinics, other locations serving particular groups (e.g., older adults), and in the home (e.g., visiting nurse services, home psychotherapy, or hospice care).

There is substantial evidence that discontinuities in treatment and fragmentation of care can increase the risk for suicide. Death by suicide in the period after discharge from inpatient psychiatric units is more frequent than at any other time during treatment.92 Similarly, the time following ED discharge also is a period of high risk for suicide.93 There is also reason for substantial concern in the period following discharge from residential addiction treatment.94 Proactive followup and active engagement strategies following discharge have been found to help reduce death by suicide and suicide attempts.65, 95

Increasing collaboration among providers is also a promising, viable, and efficient way to increase access to suicide prevention and treatment services. This approach can help minimize prejudice and discrimination, while increasing opportunities to improve overall health outcomes. Even in cases when full integration may not be feasible, increased coordination of services and continuity of care can greatly improve care and lead to better patient outcomes.

### Objective 8.1 Promote the adoption of “zero suicides” as an aspirational goal by health care and community support systems that provide services and support to defined patient populations

In recent years, a small number of health care and community support systems that provide health care services to defined populations (also referred to as “boundaried” systems) have adopted a “zero suicides” goal for the population under their care. Within these types of health care systems, the goal of eliminating suicide can help set into place system-wide changes that enhance service access and quality through continuous improvement. Managing a system of care to achieve the goal of zero suicides requires organizations to evaluate performance rigorously and use adverse events as opportunities to improve their capacity to save lives. It also requires putting into place mechanisms to support clinicians in the aftermath of a patient’s death by suicide.

Historically, there have been varied responses to providers who have lost patients to suicide. These have ranged from the sense that some deaths are inevitable in severe cases of mental illness, just as they are in cases of advanced cancer or heart failure, to the view that each death must reflect a failure or lapse in treatment. Although neither of these perspectives is universal, it is clear that each death represents an opportunity for systems and providers to evaluate the care they have delivered and to consider opportunities for improvement. Part of the zero suicides strategy may be for health systems to conduct a root cause analysis (a structured process used to determine the causes of an event) of suicide attempts and deaths, and to use findings to try to continuously improve service quality by focusing on systems issues rather than individual blame. The HFHS Perfect Depression Care program provides an example of this promising approach.49, 96

### Objective 8.2 Develop and implement protocols for delivering services for individuals with suicide risk in the most collaborative, responsive, and least restrictive settings

Trusting therapeutic relationships are fundamental to reducing suicide risk and promoting recovery and wellness. These relationships are most productive when the patient is actively engaged in making choices that will keep him or her safe. There is a need to promote culturally appropriate strategies that will foster therapeutic alliances between patients and providers. The personal needs, wishes, and resources of the patient should be the foundation for developing a plan for continuing care and safety. This plan should be developed through direct and open communication and should engage and empower the patient. Where appropriate and practical, families and significant others should be engaged and empowered as well.

Psychiatric hospitalization, voluntary or involuntary, may be an effective mechanism for preventing suicide over the short term. However, the decision to hospitalize could be a barrier to the development of a long-term therapeutic alliance between the patient and his or her mental health providers. Short-term gains in safety may be neutralized or even outweighed by longer-term increases in risk if patients are reluctant to disclose suicidal thoughts because they perceive a lack of acceptance or sensitivity to cultural values, or if they are afraid of losing their autonomy or being forced into treatment. One way to address this trade-off is to ensure that inpatient psychiatric units are recovery-oriented and prepared to ensure continuity of care at the point of discharge. Another strategy is to develop alternatives to hospitalization for persons who are not at imminent risk.

There is also a need to identify alternatives to coercion, restraint, and involuntary treatment as ways to ensure the safety of patients in crisis. Because past trauma or abuse increases the risk for suicide, confining people against their will can retraumatize patients. It may also make these patients reluctant to seek help in the future for fear of being discriminated against, traumatized, or imprisoned. There is a need to develop and implement protocols for delivering services in the least restrictive settings consistent with safety.

Protocols should be developed and implemented for delivering services to persons with high suicide risk that promote collaboration and responsiveness. At a minimum, these protocols would instill attitudes and beliefs on the value of shared responsibility and collaborative care and promote effective communication with patients, families, and significant others.

### Objective 8.3 Promote timely access to assessment, intervention, and effective care for individuals with a heightened risk for suicide

Timely access to care is critically important to individuals in crisis. Crisis hotlines, online crisis chat/intervention services, self-help tools, crisis outreach teams, and other services play an important role in providing timely care to patients with high suicide risk. Virtual or remote care, such as telephone calls to crisis hotlines, and counseling by telephone, texting, or the Internet allow individuals in crisis to access help 24 hours a day, 7 days a week. This type of care typically is available at low or no cost to individuals in crisis and provides immediate access, convenience, and a higher level of anonymity than face-to-face therapy arrangements.

Providing detailed instructions about how to access care 24 hours a day, 7 days a week is a critical part of safety planning for providers working with patients at high risk. It is unrealistic to expect individual providers to be available at all hours. There may be limitations to the coverage that provider organizations can offer. Providing patients with information about how and when to access care in an ED may be necessary but not sufficient. Access to virtual or remote care is critical for augmenting the care provided at clinics and private practices, which usually have limited hours of operation, and also can be useful for reaching rural and underserved populations.

### Objective 8.4 Promote continuity of care and the safety and well-being of all patients treated for suicide risk in emergency departments or hospital inpatient units

Patients leaving the ED or hospital inpatient unit after a suicide attempt, or otherwise at a high risk for suicide, require rapid, proactive followup. Having survived a suicide attempt is one of the most significant risk factors for later death by suicide. The risk is particularly high in the weeks and months following the attempt, including the period after discharge from acute care settings such as EDs and inpatient psychiatric units.97, 98 Among patients with high suicide risk, particularly those who have attempted suicide, immediate followup and continuity of care are crucial to promoting positive outcomes.43

When patients with high suicide risk come to an ED, they may receive limited mental health services,99 may not receive adequate treatment for underlying mental health or substance use disorders, and frequently do not receive any followup care.100, 101 All patients who present to the ED for a suicide attempt or who are at risk for suicide require mental health evaluations. Should they not require acute inpatient care, they should be informed about risks during the discharge period and be referred for mental health services before discharge from the ED. However, although referral is necessary, it may not be sufficient. There is increasing evidence that specific outreach programs can be highly effective in increasing the proportion of patients who engage in mental health care after hospitalization.102

For patients who are transferred from the ED to medical-surgical services for the treatment of injuries related to a suicide attempt, followup mental health evaluations should be conducted before discharge to decide between transfer to a mental health inpatient unit or referral to outpatient care. These evaluations should consider the support available from family and friends and the patient’s clinical status. Before a decision to discharge is made, followup appointments for mental health care should be made and patients (and families or friends) should be coached about the importance of continuity in care.

All patients who are admitted to an inpatient mental health unit require followup mental health services after discharge, as well as connections to community-based supports. Health care systems should seek to dramatically shorten the time between inpatient discharge and followup outpatient treatment. For example, EDs and others providing services to these patients could set a goal of ensuring that followup occurs within 48 hours or, at most, within a week of discharge.

Continuity of care following a suicide attempt should represent a collaborative approach between patient and provider that gives the patient a feeling of connectedness. Strategies may include telephone reminders of appointments, providing a “crisis card” with emergency phone numbers and safety measures, and/or sending a letter of support.103 Many types of motivational counseling and case management can also be used to promote adherence to the recommended treatment.

### Objective 8.5 Encourage health care delivery systems to incorporate suicide prevention and appropriate responses to suicide attempts as indicators of continuous quality improvement efforts

Health care delivery systems should evaluate performance rigorously and incorporate suicide prevention and appropriate responses to suicide attempts in continuous quality improvement efforts, as a way to improve their capacity to save lives at risk. Such efforts could include formal root cause analyses of suicide attempts and deaths by suicide, supervisory reviews, reviews of aggregate data for trends, or focused quality assurance studies on issues related to suicide risk. Health care systems should consider whether the implementation of lessons learned can be part of a strategy aimed at eliminating suicides and part of overall quality improvement. Such reviews should focus on identifying systemic issues where improvement holds promise for increasing the quality of care, and should not focus on attributing blame to providers or to individuals in crisis.

### Objective 8.6 Establish linkages between providers of mental health and substance abuse services and community-based programs, including peer support programs

To be effective in suicide prevention, providers of mental health and substance abuse services must coordinate services with each other and with other service providers in the community. It is generally recognized that mental health and substance abuse services can have a greater impact when community gatekeepers refer at-risk patients to these specialized providers. The effects of mental and substance use services can also be enhanced when specialized providers refer patients to community programs that can augment care.

Timely and effective cooperation, collaboration, and communication between mental health and substance use providers and sources of support in the community are critical to promote patient safety and recovery. Mental health and substance abuse providers should develop linkages with community-based supports such as community agencies for suicide prevention, mental health advocacy organizations, aging services organizations, veterans support organizations, and programs providing peer support services. These programs can help foster a sense of connection and belonging and provide critically needed services including employment and vocational help, housing assistance, social interactions that are not focused on illness, and peer support.

### Objective 8.7 Coordinate services among suicide prevention and intervention programs, health care systems, and accredited local crisis centers

Increased collaboration and coordination among suicide prevention programs, health care systems addressing mental health and substance abuse, and local crisis centers can help provide a continuum of care for individuals at risk for suicide. Health care providers and organizations that conduct assessments of suicide risk must have access to mental health and substance abuse services for patients with high suicide risk. Such support can be obtained from local mental health providers or can be provided remotely (e.g., telephone, online) by crisis service organizations.

A growing network of crisis services organizations can serve an effective option for continuous care. Many, including the certified crisis centers in the National Suicide Prevention Lifeline (800–273–TALK/8255) network, offer trained personnel who can conduct remote assessments, coordinate linkage for care, and provide followup for persons at risk. A prototype for integrating crisis and clinical services is the VA crisis line and its relationship with the National Suicide Prevention Lifeline. In the VA system, call responders regularly interact with providers at the medical center nearest to the patient to arrange and facilitate followup.

The Massachusetts Statewide Advocacy for Veterans’ Empowerment (SAVE) program provides another example of the benefits of coordinating services.104 The program works to prevent suicide and mental health distress by serving as a liaison with the various agencies within the federal and state governments, thereby ensuring access to benefits and services that address these issues and contribute to a positive transition to civilian life.

### Objective 8.8 Develop collaborations between emergency departments and other health care providers to provide alternatives to emergency department care and hospitalization when appropriate, and to promote rapid followup after discharge

Patients with high suicide risk often are treated at EDs, and may be hospitalized as a way to prevent a suicide attempt. Although this can be an effective strategy and is necessary as a safety measure, there is a need to develop alternatives. Research has shown that the proportion of individuals attempting suicide who are discharged directly from the ED to the community has been increasing.105 Discharge from the ED may be clinically appropriate, but it requires that adequate supports and followup be in place. In addition, not every ED has the capacity to provide suicide risk assessment.99 One strategy is for primary care, mental health, and substance use programs to establish mechanisms to facilitate rapid access to their services when patients are in crisis. Another is to develop alternative services that can be accessed through EDs. For example, a crisis line could arrange for appointments with providers in the community while the patient is in the ED.

Collaborations among EDs and community providers, such as health and mental health centers, crisis centers, hotlines, and outreach teams, can improve the quality and continuity of care for these high-risk patients. These collaborations can help expand alternatives to EDs, such as the same day scheduling for mental health services and in-home crisis care, and secure rapid and continuous followup after discharge. Plans for discharge from the ED must incorporate linkages to other necessary levels of care (e.g., intensive outpatient, private therapist, pharmacological therapy). Organizations must recognize, accept, and implement shared service responsibilities among various clinical staff within the organization and among providers in the larger community.

## Goal 9 Promote and implement effective clinical and professional practices for assessing and treating those identified as being at risk for suicidal behaviors

Primary care physicians play an important role in the assessment and management of suicide risk. It is estimated that 75 percent of individuals who die by suicide are in contact with a primary care physician in the year before their death, and that 45 percent do so within one month of their death.106 In contrast, only 20 percent of these patients saw a mental health professional in the preceding month.

Effective clinical and professional practices in the assessment and treatment of individuals with high suicide risk can help prevent these individuals from acting on their despair and distress in self-destructive ways. These practices should be grounded in evidence-based care or in best practices, in cases where promising approaches have been identified but more research is needed.

Suicide risk assessment programs often target patients with known risk factors for suicide, including those who have previously expressed suicidal thoughts or made a suicide attempt and persons with mood or substance use disorders. Treatment of patients with suicide risk often includes medication (e.g., antidepressants) and psychosocial approaches such as cognitive-behavioral therapy and supportive counseling. Because suicide attempts are known to be a strong predictor of future attempts and deaths by suicide, continuity of care is critical for these patients. Effective clinical care should include monitoring patients for a suicide attempt after an ED visit or hospitalization and providing outreach, mental health followup, therapy, and case management.

### Objective 9.1 Adopt, disseminate, and implement guidelines for the assessment of suicide risk among persons receiving care in all settings

The assessment of suicide risk is critical to identifying high-risk individuals and providing needed services and supports. Assessment of suicide risk should be an integral part of primary care, hospital care (particularly ED care), care for mental and substance use disorders, crisis response (e.g., help lines, mobile teams, first responders, crisis chat services), and of the care provided in skilled nursing facilities. Any person identified as being at a possible risk for suicide should be formally assessed for suicidal thoughts, plans, intent, access to lethal means, a history of previous attempts, the presence of acute risk factors (including problems in the family and other social relationships, work or school, finances, and the legal system), and level of risk. Persons identified as being at risk for suicide should have immediate access to needed clinical care and support.

Tools and methods to help detect risk, conduct assessments, intervene for safety, and deliver quality treatment and support are available but not widely used. Research has not yet identified a simple, easily administered scale leading to a score that can provide a quantifiable substitute for clinical decision-making and judgment. However, reliable and valid instruments do exist and can be a useful component of a full evaluation. Guidelines for risk assessment, along with appropriate tools and protocols, must be disseminated among all settings that provide care for individuals with suicide risk.

Strategies for assessing suicide risk should be tailored to the individual and context. For individuals in primary care without known risk factors, a staged approach may be useful, where evaluations for suicide risk are conducted when patients have a positive screen or show evidence of a mental health or substance use disorder or a chronic pain syndrome. In these cases, evaluations for the risk of suicide should be conducted at the initial diagnostic and treatment planning evaluation and when there are significant changes in symptoms and treatments. For individuals who have previously been at high risk, evaluations should be conducted on a frequent, regularly scheduled basis, when there are significant changes in symptoms or treatments, and when a person experiences stressful events. Guidelines for suicide risk assessment should be meaningfully related to the training objectives listed in Objective 7.2 of this National Strategy.

### Objective 9.2 Develop, disseminate, and implement guidelines for clinical practice and continuity of care for providers who treat persons with suicide risk

Disjointed service delivery, lack of effective communication among caregivers, and clinician concerns associated with the possible loss of a patient to suicide are barriers to effective clinical care for persons with suicide risk. These barriers can create an environment where a person with suicide risk may feel reluctant to disclose suicidal thoughts and feelings to a helping professional because he or she senses discomfort and is afraid of being automatically referred to inpatient care. Unprepared caregivers, acting in isolation, are more likely to experience heightened anxiety than trained caregivers empowered to share the responsibility for managing suicide risk.

Guidelines on the treatment of specific mental health conditions are necessary, but they are not sufficient. There is a need for guidelines for clinical practice that address the care indicated for individuals identified as being at risk for suicide. These guidelines should reflect the latest evidence and best practices in care for patients with suicide risk. They should indicate how care should be modified to address the needs of patients at risk for suicide and specify what services and interventions should be provided to supplement care directed toward the underlying condition(s). At a minimum, these guidelines should address:

■ Patient-centered care;
■ Recovery-oriented mental health services;
■ Building protection and resilience;
■ Suicide prevention specific intervention planning and review;
■ Safety planning;
■ Effective therapeutic alliances;
■ Communication among providers;
■ Alignment of clinical approaches with needs (e.g., underlying psychiatric and/or substance use disorders, trauma support, complicated grief);
■ Immediate access to crisis services;
■ Continuity of care, including immediate followup after discharge from an inpatient unit following a suicide attempt; and
■ Appropriate empowerment of families and significant others in treatment, peer support, and post-discharge followup.

### Objective 9.3 Promote the safe disclosure of suicidal thoughts and behaviors by all patients

Settings that provide care to patients with suicide risk must be nonjudgmental and psychologically safe places in which to receive services. Patients who have thoughts of suicide may feel embarrassed, guilty, and fearful of disclosing their thoughts and feelings to others. These patients may also fear losing autonomy or the ability to make their own treatment decisions. To address these barriers to treatment, collaborative and non-coercive approaches should be used whenever possible. Health care providers and other caregivers must have the skills required to promote disclosure. Individuals contacting a potential helper must feel comfortable to disclose their desire or intent to die and their thoughts of suicide. They must feel confident that the potential caregiver will be accepting and in a position to offer nonjudgmental help.

Anxiety about asking suicide-related questions may also be a barrier to identifying individuals at risk. Education, training, and rehearsal of ways to address the disclosure of suicide risk can help ease these concerns. System-based approaches that give providers access to resources that can help them manage someone who is suicidal also can help reduce provider anxiety regarding the disclosure of suicide-related thoughts and behaviors. For example, VA places a suicide prevention coordinator at each medical center, as a resource for providers who need to make difficult clinical judgments.

### Objective 9.4 Adopt and implement guidelines to effectively engage families and concerned others, when appropriate, throughout entire episodes of care for persons with suicide risk

Family members, significant others, and close friends can play an important role in enhancing the safety of patients with suicide risk. These individuals should be trained to understand, monitor, and intervene with loved ones who are at risk for suicide. Because the exact timing of suicidal behaviors is very difficult to predict, it is important that key members of the family unit and social support network be knowledgeable about risk factors and about how to help protect an individual from suicide. These individuals (family members/support network) should know when to contact treatment providers or emergency services and how to take reasonable precautions to reduce access to lethal means. Family members need to feel able to ask directly about suicidal thoughts, but should not be placed in the position of providing around-the-clock “suicide watches.”

Involving the patient’s family and/or close friends is an important way to help ensure patients leaving the ED after a suicide attempt or those being discharged after inpatient care keep their followup appointments. These individuals also can help support patient adherence to important treatment decisions and followup arrangements.

Contact and collaboration between providers and patients’ family members or friends usually requires consent from the patient. Engaging the patient in arranging such contact and collaboration is important as a matter of both autonomy and effectiveness. However, in the context of suicide prevention, limited exceptions to these principles may be necessary.

Guidelines should be developed and implemented to help providers balance respecting autonomy versus ensuring safety in their work with patients with high suicide risk and their families. As an example, the American Association of Suicidology has developed a set of recommendations for inpatient and residential patients at high risk for suicide.107 The recommendations seek to enhance the provision of care in inpatient and residential facilities and to promote, when possible, the involvement of families as meaningful members of the treatment team.

### Objective 9.5 Adopt and implement policies and procedures to assess suicide risk and intervene to promote safety and reduce suicidal behaviors among patients receiving care for mental and/or substance use disorders

Strategies for monitoring patients and identifying those at risk in a number of contexts are also needed. Monitoring should be more frequent and more focused for those people known to have risk factors such as mental or substance use disorders, chronic pain, or disability. Monitoring should be more intensive for those identified as being at high risk for suicidal behaviors. Clinical care for individuals at a high risk for suicide, including those who have survived a suicide attempt, should recognize and support recovery and should also be based on the understanding that individuals remain at risk for extended periods of time. Regularly scheduled monitoring should focus on evaluating changes in symptoms of medical and mental health conditions, changes in protective factors such as social networks, the occurrence and impact of stressful events, and the recurrence of suicidal ideation, plans, or intent.

Specialty centers that provide care for mental and substance use disorders should have in place policies, procedures, and programs designed to identify the level of suicide risk and intervene to prevent suicide among their patients. Evaluation of these policies and procedures over time can contribute to the more effective and efficient delivery of health care to patients with high suicide risk.

Although assessment and intervention are different processes, policies and procedures in these two areas must be coordinated. Put simply, a lack of knowledge and resources to respond to patients found to be at high risk for suicide could represent a barrier to case identification. Policies and procedures should recognize that managing a patient at a high risk for suicide can take more time than a standard encounter and may require the involvement of more than one provider.

As noted earlier, interventions for patients at risk for suicide should combine care for underlying conditions with strategies that directly address suicide risk. At the same time, it is important to reevaluate treatments for mental health and substance use disorders to ensure that they are appropriate, and that they address both the management of symptoms and recovery. For those with a serious mental illness, ensuring that the treatment plan is recovery oriented can be lifesaving.

Collaborative safety planning has been found to be a component of effective treatment of suicidal risk. Health systems such as VA have begun to require safety planning as an intervention within their systems for patients at high risk.

### Objective 9.6 Develop standardized protocols for use within emergency departments based on common clinical presentation to allow for more differentiated responses based on risk profiles and assessed clinical needs

EDs are key settings for providing services to persons with high suicide risk, particularly those who have attempted suicide. In 2009, 374,486 people were treated in EDs for self-inflicted injuries.1

Standardized protocols should be developed for use within EDs that allow for differentiated responses based on risk profiles and assessed clinical needs (e.g., intoxicated and suicidal, chronically suicidal, suicidal with active psychosis). These protocols should emphasize patient-centered and stepped approaches that allow relative suicide risk to be assessed and matched with a continuum of services. For example, individuals who are identified as being at a high risk for suicide may require intensive outpatient suicide-specific mental health treatment. Those who are intoxicated and suicidal will, in general, have to be evaluated after they have become sober before they can be discharged. Seriously ill patients with high suicide risk may require partial hospitalization or short-term psychiatric inpatient stays.

### Objective 9.7 Develop guidelines on the documentation of assessment and treatment of suicide risk and establish a training and technical assistance capacity to assist providers with implementation

The proper documentation of assessment and treatment can improve the care of patients with high suicide risk and, at the same time, protect providers from allegations of malpractice. A proper assessment should identify the severity of a patient’s risk for suicide, allowing for the development of critical treatment plan determinations. Decisions such as whether to hospitalize or whether a patient can be treated on an outpatient basis depend on the foreseeable risk of suicide and the patient’s ability to work collaboratively to stay safe. The type of treatment that is recommended should be appropriate for the patient’s level of risk, needs, and preferences. These issues require careful documentation. Training materials on evidence- based psychotherapies for suicide prevention and safety planning should include tools to support these interventions, such as chart templates used to document their delivery.

## Goal 10 Provide care and support to individuals affected by suicide deaths and attempts to promote healing and implement community strategies to help prevent further suicides

The mental health and medical communities often fail to provide needed services to individuals who have attempted suicide and to those who have been affected by a suicide attempt or death. Individuals who have made a suicide attempt may receive insufficient care in the community. Those who have been bereaved by suicide may receive little or no guidance or support for the traumatic impact of this occurrence.

While most individuals bereaved by suicide recover from the trauma, many people may suffer alone and experience harmful effects that can be devastating and sometimes long lasting. For these reasons, it is crucial to pay attention to the needs of these potentially vulnerable but underserved groups. In addition, deaths by suicide can affect whole organizations and communities, leading to concerns regarding suicide contagion, particularly among youth.

### Objective 10.1 Develop guidelines for effective comprehensive support programs for individuals bereaved by suicide and promote the full implementation of these guidelines at the state/territorial, tribal, and community levels

Guidelines for providing care and support to individuals bereaved by suicide are needed. Communities vary tremendously in the extent to which they provide these types of support services. Individuals bereaved by suicide often have difficulty finding the services they need when they are ready to access them. Developing comprehensive national guidelines for effective support will provide a “roadmap” for the kinds of services that communities can work to provide for these groups. This support can include, but is not limited to, outreach teams of professionals and trained individuals who have been bereaved by suicide, face-to-face and online support groups, memorial services, and other opportunities for those who have been bereaved by suicide to interact with each other and find positive and culturally appropriate ways to deal with their grief.

The Action Alliance’s Task Force on Survivors of Suicide Loss is working toward the development of consensus guidelines for the creation and implementation of effective, comprehensive support programs for individuals affected by a suicide loss. The Task Force will review existing evidence regarding model services and programs, draft consensus guidelines incorporating input from various groups, and submit the guidelines for inclusion in the Best Practices Registry for Suicide Prevention.

### Objective 10.2 Provide appropriate clinical care to individuals affected by a suicide attempt or bereaved by suicide, including trauma treatment and care for complicated grief

Exposure to a suicide attempt or death, particularly of someone who is psychologically close, can have harmful effects on individuals and families, including increasing the risk for suicide in the person exposed.39 Family and friends of individuals who attempt suicide can have similar reactions. The actual or threatened loss of a loved one by suicide is often shocking, painful, and unexpected. The reactions can be intense, complex, and long lasting, and may be accompanied by powerful emotions such as denial, anger, guilt, and shame. Each person will experience this grief in a unique way.

Because of the prejudice attached to suicide, family members and friends may not know how to help someone who has been affected by a suicide loss or attempt. Shame and embarrassment may prevent the person from reaching out for help. While support groups can be very helpful, individuals affected by suicide must also have access to knowledgeable professional services and supports.

### Objective 10.3 Engage suicide attempt survivors in suicide prevention planning, including support services, treatment, community suicide prevention education, and the development of guidelines and protocols for suicide attempt survivor support groups

Making a suicide attempt is a risk factor for later death by suicide.11 Promoting the positive engagement of those who have attempted suicide in their own care is likely crucial in successfully reducing risk for suicide. In addition, these individuals can be powerful agents for challenging prejudice and activating hope for others.

Most successful suicide prevention strategies have used multiple components, but one underutilized intervention in suicide prevention has been peer support. Appropriate peer support plays an important role in the treatment of mental and substance use disorders and holds a similar potential for helping those at risk for suicide. Guidelines and protocols are needed to support the development of such services for those who have attempted suicide, as well as technical assistance to assist with the dissemination and implementation of these tools.

### Objective 10.4 Adopt, disseminate, implement, and evaluate guidelines for communities to respond effectively to suicide clusters and contagion within their cultural context, and support implementation with education, training, and consultation

The 2001 National Strategy described the phenomena of “suicide contagion” and “suicide clusters.” Contagion has been described as the process by which exposure to suicidal behaviors from interpersonal contacts or the media can lead to an increase in suicidal behaviors, particularly among adolescents and young adults. A suicide cluster has been defined as a group of suicides or suicide attempts, or both, that occur closer together in time and space than would normally be expected in a given community.67

CDC has estimated that cluster suicides may account for 1 to 5 percent of suicides among adolescents and young adults.67 In 1988, CDC issued recommendations for communities to use in the prevention and containment of suicide clusters.67 These recommendations provide an important foundation for community suicide prevention efforts but have not been routinely implemented in communities experiencing clusters. In addition, the effect of differing cultural contexts (e.g., in American Indian/Alaska Native communities), has not been systematically analyzed, nor has the effectiveness of the recommendations been evaluated.

### Objective 10.5 Provide health care providers, first responders, and others with care and support when a patient under their care dies by suicide

Clinicians, first responders, emergency personnel, and other medical professionals who lose a patient to suicide should be provided with support to deal with the emotional aftermath of this traumatic event. Such support should address trauma and grief reactions and potential suicide risk among caregivers. Mechanisms for review of such deaths should avoid blaming the caregiver. Instead, the goal should be to respond to the caregiver’s need for support and help the provider respond to patients who may be at risk for suicide in the future.

What You Can Do to Advance the Goals and Objectives in Strategic Direction 3 of the National Strategy for Suicide Prevention

##### The Federal Government Can

■ Promote access to high-quality mental health services and facilitate the integration of mental health services into a range of settings (e.g., Federally Qualified Health Centers, Bureau of Prisons, Indian Health Service, and VA facilities). (Objectives 8.3 and 8.6)
■ Update and revise federal publications addressing the appropriate response after a suicide. (Objective 10.4)

##### State, Territorial, Tribal, and Local Governments Can

■ Disseminate information about the National Suicide Prevention Lifeline and other local or regional crisis lines. (Objective 8.3)
■ Promote the availability of online support services and crisis outreach teams. (Objective 8.3)
■ Develop protocols and improve collaboration among crisis centers, law enforcement, mobile crisis teams, and social services to ensure timely access to care for individuals with suicide risk. (Objective 8.3)

##### Businesses and Employers Can

■ Ensure that counselors in an employee assistance program (EAP) are well equipped to assess and manage suicide risk. (Objective 9.1)
■ Ensure that mental health services offered to employees include grief counseling for individuals bereaved by suicide. (Objective 10.1)

##### Health Care Systems, Insurers, and Clinicians Can

■ Implement patient-informed alternatives to hospitalization for individuals with suicide risk. (Objective 8.2)
■ Develop alternatives to treatment in an emergency department, such as same-day scheduling for mental health services and in-home crisis care. (Objective 8.8)
■ Develop and implement protocols to ensure immediate and continuous followup after discharge from an ED or inpatient unit. (Objective 8.4)
■ Educate family members and significant others about appropriate steps they can take to support individuals at suicide risk during treatment and/or after discharge from an ED or inpatient unit. (Objective 9.4)

##### Schools, Colleges, and Universities Can

■ Educate students who are in training to become mental health, social service, or health care providers on the identification and treatment of individuals at high risk for suicide. (Objective 9.2)

##### Nonprofit, Community-, and Faith-Based Organizations Can

■ Coordinate the services of community-based and peer-support programs with the support available from local providers of mental health and substance abuse services to better serve individuals at risk for suicide. (Objective 8.6)

##### Individuals and Families Can

■ Provide appropriate followup support to family members of individuals who have been discharged from an ED or inpatient unit, including reminders about appointments, and information on compliance with treatment plans and on ways to reduce access to lethal means. (Objective 9.4)
■ Learn when to contact treatment providers or emergency services for loved ones who are at risk for suicide. (Objective 9.4)