# References

1 Centers for Disease Control and Prevention. Fatal injury data, 2009. Web-based Injury Statistics Query and Reporting System.
2 Mcintosh JL. (2012). U.S.A. suicide: 2009 official final data.
3 Substance Abuse and Mental Health Services Administration. (2011). Utilization of mental health services by adults with suicidal thoughts and behavior.
4 Centers for Disease Control and Prevention. (2012). Youth risk behavior surveillance—United States, 2011. MMWR.
5 U.S. Public Health Service. (1999). The Surgeon General’s call to action to prevent suicide.
6 U.S. Department of Health and Human Services. (2001). National strategy for suicide prevention: goals and objectives for action.
7 Suicide Prevention Resource Center (SPRC) and Suicide Prevention Action Network USA (SPAN USA). (2010). Litts David, editor. Charting the future of suicide prevention: a 2010 progress review of the National Strategy and recommendations for the decade ahead.
8 Harris EC, Barraclough B. (1997). Suicide as an outcome for mental disorders. A meta-analysis. Br J Psychiatry.
9 (2002). Goldsmith S, Pellmar T, Kleinman A, Bunney W, editors. Reducing suicide: a national imperative.
10 Suicide Prevention Resource Center. Understanding risk and protective factors for suicide: a primer for preventing suicide.
11 Fowler JC. (2012). Suicide risk assessment in clinical practice: pragmatic guidelines for imperfect assessments. Psychotherapy.
12 Sisask M, Varnik A. (2012). Media roles in suicide prevention: a systematic review. Int J Environ Res Public Health.
13 Pompili M, Serafini G, Innamorati M, et al. (2010). Suicidal behavior and alcohol abuse. Int J Environ Res Public Health.
14 Swahn MH, Ali B, Bossarte RM, et al. (2012). Self-harm and suicide attempts among high-risk, urban youth in the U.S.: shared and unique risk and protective factors. Int J Environ Res Public Health.
15 Lubell KM, Vetter JB. (2006). Suicide and youth violence prevention: the promise of an integrated approach. Aggress Violent Behav.
16 Knox KL, Litts DA, Talcott GW, Feig JC, Caine ED. (2003). Risk of suicide and related adverse outcomes after exposure to a suicide prevention programme in the US Air Force: cohort study. BMJ.
17 Centers for Disease Control and Prevention. Fatal injury data, 2008. Web-based Injury Statistics Query and Reporting System.
18 Crosby AE, Han B, Ortega LA, Parks SE, Gfroerer J. (2011). Suicidal thoughts and behaviors among adults aged ≥18 years—United States, 2008–2009. MMWR Surveill Summ.
19 Centers for Disease Control and Prevention. National Violent Death Reporting System.
20 Centers for Disease Control and Prevention. WISQARS™—Your source for U.S. injury statistics.
21 Borowsky IW, Resnick MD, Ireland M, Blum RW. (1999). Suicide attempts among American Indian and Alaska Native youth: risk and protective factors. Arch Pediatr Adolesc Med.
22 Frank ML, Lester D. (2002). Self-destructive behaviors in American Indian and Alaska Native high school youth. Am Indian Alsk Native Ment Health Res.
23 Freedenthal S, Stiffman AR. (2004). Suicidal behavior in urban American Indian adolescents: a comparison with reservation youth in a southwestern state. Suicide Life Threat Behav.
24 Valtonen H, Suominen K, Mantere O, Leppamak iS, Arvilommi P, Isometsa ET. (2005). Suicidal ideation and attempts in bipolar I and II disorders. J Clin Psychiatry.
25 Tondo L, Isacsson G, Baldessarini R. (2003). Suicidal behaviour in bipolar disorders: risk and prevention. CNS Drugs.
26 Palmer BA, Pankratz VS, Bostwick JM. (2005). The lifetime risk of suicide in schizophrenia: a reexamination. Arch Gen Psychiatry.
27 Karch DL, Logan J, Patel N. (2011). Surveillance for violent deaths—National Violent Death Reporting System, 16 states, 2008. MMWR Surveill Summ.
28 Tondo L, Baldessarini RJ, Hennen J, et al. (1999). Suicide attempts in major affective disorder patients with comorbid substance use disorders. J Clin Psychiatry.
29 (2011). Berman AL, Pompili M, editors. Medical conditions associated with suicide risk.
30 Lofthouse N, Yager-Schweller J. (2009). Nonsuicidal self-injury and suicide risk among adolescents. Curr Opin Pediatr.
31 Hawton K, Harriss L, Zahl D. (2006). Deaths from all causes in a long-term follow-up study of 11,583 deliberate self-harm patients. Psychol Med.
32 World Health Organization and International Association for Suicide Prevention. (2007). Preventing suicide in jails and prisons.
33 Hayes L. (2005). Suicide prevention in correctional facilities. Scott C, Gerbasi J, editors. Handbook of correctional mental health.
34 Mumola C, Noonan M. (2008). Deaths in custody statistical tables.
35 Mumola C. (2005). Suicide and homicide in state prisons and local jails.
36 Leslie LK, James S, Monn A, Kauten MC, Zhang J, Aarons G. (2010). Health-risk behaviors in young adolescents in the child welfare system. J Adolesc Health.
37 Pilowsky DJ, Wu LT. (2006). Psychiatric symptoms and substance use disorders in a nationally representative sample of American adolescents involved with foster care. J Adolesc Health.
38 Marshal MP, Dietz LJ, Friedman MS, et al. (2011). Suicidality and depression disparities between sexual minority and heterosexual youth: a meta-analytic review. J Adolesc Health.
39 Jordan J, McIntosh JL. (2011). Grief after suicide: Understanding the consequences and caring for the survivors.
40 Brown GK, Ten Have T, Henriques GR, Xie SX, Hollander JE, Beck AT. (2005). Cognitive therapy for the prevention of suicide attempts: a randomized controlled trial. JAMA.
41 Linehan MM, Comtois KA, Murray AM, et al. (2006). Two-year randomized controlled trial and follow-up of dialectical behavior therapy vs therapy by experts for suicidal behaviors and borderline personality disorder. Arch Gen Psychiatry.
42 Knox KL, Kemp J, McKeon R, Katz IR. (2012). Implementation and early utilization of a suicide hotline for veterans. Am J Public Health.
43 Knesper DJ. (2010). Continuity of care for suicide prevention and research: suicide attempts and suicide deaths subsequent to discharge from the emergency department or psychiatry inpatient unit.
44 Wasserman D, Rihmer Z, Rujescu D, et al. (2012). The European Psychiatric Association (EPA) guidance on suicide treatment and prevention. Eur Psychiatry.
45 Centers for Disease Control and Prevention. Strategic direction for the prevention of suicidal behavior: promoting individual, family, and community connectedness to prevent suicidal behavior.
46 Suicide Prevention Resource Center. Best practices registry (BPR) for suicide prevention.
47 National Prevention Council. (2011). National prevention strategy.
48 U.S. Department of Health and Human Services, Office of Minority Health. (2001). National standards for culturally and linguistically appropriate services in health care: final report.
49 Coffey CE. (2007). Building a system of perfect depression care in behavioral health. Jt Comm J Qual Patient Saf.
50 While D, Bickley H, Roscoe A, et al. (2012). Implementation of mental health service recommendations in England and Wales and suicide rates, 1997–2006: a cross-sectional and before-and-after observational study. Lancet.
51 Kellam SG, Mackenzie AC, Brown CH, et al. (2011). The good behavior game and the future of prevention and treatment. Addict Sci Clin Pract.
52 The Safe States Alliance. (2011). Preventing violence: roles for public health agencies.
53 United Nations. (1996). Prevention of suicide: guidelines for the formulation and implementation of national strategies.
54 Centers for Medicare & Medicaid Services, U.S. Department of Health and Human Services. Medicare and Medicaid programs: electronic health record incentive program–stage 2.
55 Noar SM, Palmgreen P, Chabot M, Dobransky N, Zimmerman RS. (2009). A 10-year systematic review of HIV/AIDS mass communication campaigns: have we made progress?. J Health Commun.
56 National Institutes of Health. (2001). Making health communication programs work.
57 Centers for Disease Control and Prevention. Gateway to health communication & social marketing practice.
58 Haas AP, Eliason M, Mays VM, et al. (2011). Suicide and suicide risk in lesbian, gay, bisexual, and transgender populations: review and recommendations. J Homosex.
59 Fox S. (2010). Mobile health 2010.
60 Luxton DD, June JD, Kinn JT. (2011). Technology-based suicide prevention: current applications and future directions. Telemed J E Health.
61 U.S. Department of Veterans Affairs. Veterans crisis line website.
62 Centers for Disease Control and Prevention. (2011). The health communicator’s social media toolkit.
63 Centers for Disease Control and Prevention. (2012). CDC’s guide to writing for social media.
64 May PA, Serna P, Hurt L, Debruyn LM. (2005). Outcome evaluation of a public health approach to suicide prevention in an American Indian tribal nation. Am J Public Health.
65 Motto JA, Bostrom AG. (2001). A randomized controlled trial of postcrisis suicide prevention. Psychiatr Serv.
66 Eisenberg ME, Resnick MD. (2006). Suicidality among gay, lesbian and bisexual youth: the role of protective factors. J Adolesc Health.
67 O’Carroll PW, Mercy JA, Steward JA. (1988). CDC recommendations for a community plan for the prevention and containment of suicide clusters. MMWR Morb Mortal Wkly Rep.
68 Recommendations for reporting on suicide.
69 Substance Abuse and Mental Health Services Administration (SAMHSA), Entertainment Industries Council (EIC). (2009). Picture this: depression and suicide prevention.
70 (2009). O’Connell M, Boat T, Warner K, editors. Preventing mental, emotional, and behavioral disorders among young people: progress and possibilities.
71 Rihmer Z. (2007). Suicide risk in mood disorders. Curr Opin Psychiatry.
72 Mann JJ, Apter A, Bertolote J, et al. (2005). Suicide prevention strategies: a systematic review. JAMA.
73 Van der Feltz-Cornelis CM, Sarchiapone M, Postuvan V, et al. (2011). Best practice elements of multilevel suicide prevention strategies. Crisis.
74 Brent DA. (2001). Firearms and suicide. Ann N Y Acad Sci.
75 Brent DA, Bridge J. (2003). Firearms availability and suicide: evidence, interventions, and future directions. Ame Behav Sci.
76 Cummings P, Koepsell TD. (1998). Does owning a firearm increase or decrease the risk of death?. JAMA.
77 Miller M, Hemenway D. (2001). Gun prevalence and the risk of suicide: A review. Harvard Health Policy Rev.
78 Ilgen MA, Zivin K, McCammon RJ, Valenstein M. (2008). Mental illness, previous suicidality, and access to guns in the United States. Psychiatr Serv.
79 Betz ME, Barber C, Miller M. (2011). Suicidal behavior and firearm access: results from the second injury control and risk survey. Suicide Life Threat Behav.
80 Miller M, Barber C, Azrael D, Hemenway D, Molnar BE. (2009). Recent psychopathology, suicidal thoughts and suicide attempts in households with and without firearms: findings from the National Comorbidity Study Replication. Inj Prev.
81 Kreitman N. (1976). The coal gas story. United Kingdom suicide rates, 1960–71. Br J Prev Soc Med.
82 Gunnell D, Fernando R, Hewagama M, Priyangika WD, Konradsen F, Eddleston M. (2007). The impact of pesticide regulations on suicide in Sri Lanka. Int J Epidemiol.
83 Suicide Prevention Resource Center (SPRC) and Suicide Prevention Action Network USA (SPAN USA). (2010). Litts David, editor. Charting the future of suicide prevention: a 2010 progress review of the National Strategy and recommendations for the decade ahead.
84 McDowell AK, Lineberry TW, Bostwick JM. (2011). Practical suicide-risk management for the busy primary care physician. Mayo Clin Proc.
85 Alexopoulos GS, Reynolds CF, Bruce ML, et al. (2009). Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry.
86 Kasckow J, Felmet K, Zisook S. (2011). Managing suicide risk in patients with schizophrenia. CNS Drugs.
87 Dolgin E. (2012). The ultimate endpoint. Nat Med.
88 Substance Abuse and Mental Health Services Administration. SAMHSA’s definition and guiding principles of recovery – answering the call for feedback.
89 Clinical Care and Intervention Task Force. (2011). Suicide care in systems framework: a report to the National Action Alliance for Suicide Prevention’s Executive Committee.
90 Katz IR, McCarthy JF, Ignacio RV, Kemp J. (2012). Suicide among veterans in 16 states, 2005 to 2008: comparisons between utilizers and nonutilizers of Veterans Health Administration (VHA) services based on data from the National Death Index, the National Violent Death Reporting System, and VHA administrative records. Am J Public Health.
91 Veterans Health Administration. (2011). Report to the Office of Mental Health Operations.
92 Valenstein M, Kim HM, Ganoczy D, et al. (2009). Higher-risk periods for suicide among VA patients receiving depression treatment: prioritizing suicide prevention efforts. J Affect Disord.
93 Weis MA, Bradberry C, Carter LP, Ferguson J, Kozareva D. (2006). An exploration of human services system contacts prior to suicide in South Carolina: an expansion of the South Carolina Violent Death Reporting System. Inj Prev.
94 Center for Substance Abuse Treatment. (2009). Addressing suicidal thoughts and behaviors in substance abuse treatment. Treatment Improvement Protocol (TIP) Series 50.
95 Fleischmann A, Bertolote JM, Wasserman D, et al. (2008). Effectiveness of brief intervention and contact for suicide attempters: a randomized controlled trial in five countries. Bull World Health Organ.
96 Hampton T. (2010). Depression care effort brings dramatic drop in large HMO population’s suicide rate. JAMA.
97 Valenstein M, Eisenberg D, McCarthy JF, et al. (2009). Service implications of providing intensive monitoring during high-risk periods for suicide among VA patients with depression. Psychiatr Serv.
98 Hunt IM, Kapur N, Webb R, et al. (2009). Suicide in recently discharged psychiatric patients: a case-control study. Psychol Med.
99 Baraff LJ, Janowicz N, Asarnow JR. (2006). Survey of California emergency departments about practices for management of suicidal patients and resources available for their care. Ann Emerg Med.
100 Olfson M, Marcus SC, Bridge JA. (2012). Emergency treatment of deliberate self-harm. Arch Gen Psychiatry.
101 Asarnow J, Baraff L, Berk M, et al. (2011). An emergency department intervention for linking pediatric suicidal patients to follow-up mental health treatment. Psych Serv.
102 Currier GW, Fisher SG, Caine ED. (2010). Mobile crisis team intervention to enhance linkage of discharged suicidal emergency department patients to outpatient psychiatric services: a randomized controlled trial. Acad Emerg Med.
103 Carter GL, Clover K, Whyte IM, Dawson AH, D’Este C. (2005). Postcards from the EDge project: randomised controlled trial of an intervention using postcards to reduce repetition of hospital treated deliberate self poisoning. BMJ.
104 Department of Veterans’ Services. Statewide Advocacy for Veterans’ Empowerment (SAVE).
105 Larkin GL, Beautrais AL. (2010). Emergency departments are underutilized sites for suicide prevention. Crisis.
106 Luoma JB, Martin CE, Pearson JL. (2002). Contact with mental health and primary care providers before suicide: a review of the evidence. Am J Psychiatry.
107 American Association of Suicidology. (2005). AAS recommendations for inpatient and residential patients known to be at elevated risk for suicide.
108 Crosby A, Ortega L, Melanson C. (2011). Self-directed violence surveillance: uniform definitions and recommended data elements, Version 1.0.
109 National Center for Injury Prevention and Control. (2009). Recommended actions to improve external-cause-of-injury coding in state-based hospital discharge and emergency department data systems.
110 Shekelle P, Bagley S, Munjas B. (2009). Strategies for suicide prevention in veterans.
111 Resnik HLP, Hathorne BC. (1973). Suicide prevention in the 70s.
112 Alcohol, Drug Abuse, and Mental Health Administration. (1989). Report of the Secretary’s Task Force on Youth Suicide: Vols. 1–4.
113 New Freedom Commission on Mental Health. (2003). Achieving the promise: transforming mental health care in America. Final report.
114 Kalafat J, Gould MS, Munfakh JL, Kleinman M. (2007). An evaluation of crisis hotline outcomes. Part 1: Nonsuicidal crisis callers. Suicide Life Threat Behav.
115 Gould MS, Kalafat J, Harrismunfakh JL, Kleinman M. (2007). An evaluation of crisis hotline outcomes. Part 2: Suicidal callers. Suicide Life Threat Behav.
116 Chandler MJ, Lalonde CE. (2008). Cultural continuity as a moderator of suicide risk among Canada’s First Nations. Kirmayer L, Valaskakis G, editors. The mental health of Canadian aboriginal peoples: transformations, identity and community.
117 Garroutte EM, Goldberg J, Beals J, Herrell R, Manson SM. (2003). Spirituality and attempted suicide among American Indians. Soc Sci Med.
118 Centers for Disease Control and Prevention. (2009). Alcohol and suicide among racial/ethnic populations – 17 states, 2005–2006. MMWR Morb Mortal Wkly Rep.
119 Walls ML, Chapple CL, Johnson KD. (2007). Strain, emotion and suicide among American Indian youth. Deviant Behav.
120 Yoder KA, Whitbeck LB, Hoyt DR, LaFromboise T. (2006). Suicidal ideation among American Indian youths. Arch Suicide Res.
121 Mock CN, Grossman DC, Mulder D, Stewart C, Koepsell TS. (1996). Health care utilization as a marker for suicidal behavior on an American Indian Reservation. J Gen Intern Med.
122 Freedenthal S, Stiffman AR. (2007). “They might think I was crazy”: young American Indians’ reasons for not seeking help when suicidal. J Adolesc Res.
123 Brave Heart MY, DeBruyn LM. (1998). The American Indian holocaust: healing historical unresolved grief. Am Indian Alsk Native Ment Health Res.
124 U.S. Department of Health and Human Services. (2010). To live to see the great day that dawns: preventing suicide by American Indian and Alaska Native youth and young adults.
125 Centers for Disease Control and Prevention. (2011). Adverse Childhood Experiences (ACE) Study.
126 Bender E. (2006). APA, AACAP suggest ways to reduce high suicide rates in Native Americans. Psychiatr News.
127 U.S. Census Bureau. (2012). The American Indian and Alaska Native population: 2010. 2010 Census Briefs.
128 Urban Indian Health Institute. (2009). Urban American Indian and Alaska Native Youth: an analysis of select national data sources.
129 Johnson T, Tomren H. (1999). Helplessness, hopelessness, and despair: identifying the precursors to Indian youth suicide. Am Indian Cult Res J.
130 LaFromboise T, Howard-Pitney B. (1995). The Zuni life skills development curriculum: description and evaluation of a suicide prevention program. J Couns Psychol.
131 Carter SL, Straits JE, Hall M. (2007). Project Venture: Evaluation of a positive, culture-based approach to substance abuse prevention with American Indian youth.
132 Mullany B, Barlow A, Goklish N, et al. (2009). Toward understanding suicide among youths: results from the White Mountain Apache tribally mandated suicide surveillance system, 2001–2006. Am J Public Health.
133 Cwik MF, Barlow A, Tingey L, Larzelere-Hinton F, Goklish N, Walkup JT. (2011). Nonsuicidal self-injury in an American Indian reservation community: results from the White Mountain Apache surveillance system, 2007–2008. J Am Acad Child Adolesc Psychiatry.
134 Crosby AE, Sacks JJ. (2002). Exposure to suicide: incidence and association with suicidal ideation and behavior: United States, 1994. Suicide Life Threat Behav.
135 Berman A. (2011). Estimating the population of survivors of suicide: Seeking an evidence base. Suicide Life Threat Behav.
136 McMenamy JM, Jordan JR, Mitchell AM. (2008). What do suicide survivors tell us they need? Results of a pilot study. Suicide Life Threat Behav.
137 U.S. Department of Justice. (2009). Juvenile suicide in confinement: a national survey.
138 Memory J. (1989). Juvenile suicides in secure detention facilities: correction of published rates. Death Stud.
139 Alessi NE, McManus M, Brickman A, Grapentine L. (1984). Suicidal behavior among serious juvenile offenders. Am J Psychiatry.
140 Brent DA. (1995). Risk factors for adolescent suicide and suicidal behavior: mental and substance abuse disorders, family environmental factors, and life stress. Suicide Life Threat Behav.
141 Gray D, Achilles J, Keller T, et al. (2002). Utah youth suicide study, phase I: government agency contact before death. J Am Acad Child Adolesc Psychiatry.
142 Hayes LM. (2009). Juvenile suicide in confinement—findings from the first national survey. Suicide Life Threat Behav.
143 Rohde P, Seeley JR, Mace DE. (1997). Correlates of suicidal behavior in a juvenile detention population. Suicide Life Threat Behav.
144 Parent D, Leiter V, Kennedy S, Livens L, Wentworth D, Wilcox S. (1994). Conditions of confinement: juvenile detention and corrections facilities.
145 Esposito CL, Clum GA. (2002). Social support and problem-solving as moderators of the relationship between childhood abuse and suicidality: applications to a delinquent population. J Trauma Stress.
146 Hayes L. (2010). National study of jail suicide: 20 years later.
147 Wasserman GA, Jensen PS, Ko SJ, et al. (2003). Mental health assessments in juvenile justice: report on the consensus conference. J Am Acad Child Adolesc Psychiatry.
148 Pilnik L. (2008). Youth suicide and self-harm: what advocates need to know. Child Law Practice.
149 Suicide Prevention Resource Center. (2008). Suicide prevention in juvenile correctional facilities: a curriculum for state agency directors.
150 Nock MK, Favazza AR. (2009). Nonsuicidal self-injury: definition and classification. Nock MK, editor. Understanding nonsuicidal self-injury: origins, assessment, and treatment.
151 Hawton K, Zahl D, Weatherall R. (2003). Suicide following deliberate self-harm: long-term follow-up of patients who presented to a general hospital. Br J Psychiatry.
152 Carter G, Reith DM, Whyte IM, McPherson M. (2005). Repeated self-poisoning: increasing severity of self-harm as a predictor of subsequent suicide. Br J Psychiatry.
153 Owens D, Horrocks J, House A. (2002). Fatal and non-fatal repetition of self-harm. Systematic review. Br J Psychiatry.
154 Brausch AM, Gutierrez PM. (2010). Differences in non-suicidal self-injury and suicide attempts in adolescents. J Youth Adolesc.
155 Beautrais AL. (2004). Further suicidal behavior among medically serious suicide attempters. Suicide Life Threat Behav.
156 Monti K, Cedereke M, Ojehagen A. (2003). Treatment adherence and suicidal behavior 1 month and 3 months after a suicide attempt: a comparison between two samples. Arch Suicide Res.
157 Cedereke M, Ojehagen A. (2002). Patients’ needs during the year after a suicide attempt. A secondary analysis of a randomised controlled intervention study. Soc Psychiatry Psychiatr Epidemiol.
158 Liberman RP. (2001). Follow-up for parasuicidal patients. Psychiatr Serv.
159 Motto JA, Bostrom AG. (2001). A randomized controlled trial of postcrisis suicide prevention. Psychiatr Serv.
160 Litts D, Beautrais A, Lezine DQ. (2008). First national conference for survivors of suicide attempts, health care professionals, and clergy and laity: Summary of workgroup reports.
161 Macro International. (2007). Lifeline service and outreach strategies suggested by suicide attempt survivors: final report of the Attempt Survivor Advisory Summit Meeting and individual interviews.
162 Substance Abuse and Mental Health Services Administration. (2011). Consumer-operated services: the evidence.
163 National Cancer Institute. (2011). PDQ depression: suicide risk in cancer patients.
164 Lonnqvist JK. (2001). Physical illness and suicide. Wasserman D, editor. Suicide: an unnecessary death.
165 DeLeo D, Meneghel G. (2001). The elderly and suicide. Wasserman D, editor. Suicide: an unnecessary death.
166 Schlebusch L. (2011). Suicide risk and cancer. Berman AL, Pompili M, editors. Medical conditions associated with suicide risk.
167 National Cancer Institute. (2011). PDQ depression: assessment, evaluation, and management of suicidal patients.
168 Akechi T, Ietsugu T, Sukigara M, et al. (2009). Symptom indicator of severity of depression in cancer patients: a comparison of the DSM-IV criteria with alternative diagnostic criteria. Gen Hosp Psychiatry.
169 Huntington G. (2003). On chorea. George Huntington, M.D. J Neuropsychiatry Clin Neurosci.
170 Fiedorowicz JG, Ruggle A, Paulsen JS. (2011). Suicide and Huntington disease. Berman AL, Pompili M, editors. Medical conditions associated with suicide risk.
171 Stenager EN, Stenager E, Koch-Henriksen N, et al. (1992). Suicide and multiple sclerosis: an epidemiological investigation. J Neurol Neurosurg Psychiatry.
172 Samuel LS. (2011). Suicide and multiple sclerosis. Berman AL, Pompili M, editors. Medical conditions associated with suicide risk.
173 Weintraub D, Stern MB. (2005). Psychiatric complications in Parkinson disease. Am J Geriatr Psychiatry.
174 Raja M. (2011). Suicide in Parkinson’s disease. Berman AL, Pompili M, editors. Medical conditions associated with suicide risk.
175 Hartkopp A, Bronnum-Hansen H, Seidenschnur AM, Biering-Sorensen F. (1998). Suicide in a spinal cord injured population: its relation to functional status. Arch Phys Med Rehabil.
176 Kennedy P, Rogers B, Speer S, Frankel H. (1999). Spinal cord injuries and attempted suicide: a retrospective review. Spinal Cord.
177 Hatcher MB, Whitaker C, Karl A. (2009). What predicts post-traumatic stress following spinal cord injury?. Br J Health Psychol.
178 (2004). Lezak MD, Howieson DB, Loring DL, editors. Neuropsychological assessment.
179 Jollant F, Bellivier F, Leboyer M, et al. (2005). Impaired decision making in suicide attempters. Am J Psychiatry.
180 Simpson G, Tate R. (2007). Suicidality in people surviving a traumatic brain injury: prevalence, risk factors and implications for clinical management. Brain Inj.
181 Jallon P. (2004). Mortality in patients with epilepsy. Curr Opin Neurol.
182 Mendez MF, Doss RC. (1992). Ictal and psychiatric aspects of suicide in epileptic patients. Int J Psychiatry Med.
183 Blumer D, Montouris G, Davies K, Wyler A, Phillips B, Hermann B. (2002). Suicide in epilepsy: psychopathology, pathogenesis, and prevention. Epilepsy Behav.
184 Janz D. (1969). Die epilepsien: spezielle pathologie und therapie.
185 World Health Organization. (2000). Preventing suicide: a resource for primary health care workers.
186 Amoozegar F, St. Germaine C, Becker WJ, Jette N. (2011). Suicide and migraines and chronic headaches. Berman AL, Pompili M, editors. Medical conditions associated with suicide risk.
187 Cooperman NA. (2011). HIV/AIDS and suicide. Berman AL, Pompili M, editors. Medical conditions associated with suicide risk.
188 Goodwin RD, Marusic A, Hoven CW. (2003). Suicide attempts in the United States: the role of physical illness. Soc Sci Med.
189 Malbergier A, de Andrade AG. (2001). Depressive disorders and suicide attempts in injecting drug users with and without HIV infection. AIDS Care.
190 Grassi L, Mondardini D, Pavanati M, Sighinolfi L, Serra A, Ghinelli F. (2001). Suicide probability and psychological morbidity secondary to HIV infection: a control study of HIV-seropositive, hepatitis C virus (HCV)-seropositive and HIV/HCV-seronegative injecting drug users. J Affect Disord.
191 Starace F, Sherr L. (1998). Suicidal behaviours, euthanasia and AIDS. AIDS.
192 Bellini M, Bruschi C. (1996). HIV infection and suicidality. J Affect Disord.
193 Kimmel PL, Cukor D, Cohen SD, Peterson RA. (2007). Depression in end-stage renal disease patients: a critical review. Adv Chronic Kidney Dis.
194 Cukor D, Peterson RA, Cohen SD, Kimmel PL. (2006). Depression in end-stage renal disease hemodialysis patients. Nat Clin Pract Nephrol.
195 Stang PE, Brandenburg NA, Lane MC, Merikangas KR, Von Korff MR, Kessler RC. (2006). Mental and physical comorbid conditions and days in role among persons with arthritis. Psychosom Med.
196 McWilliams LA, Clara IP, Murphy PD, Cox BJ, Sareen J. (2008). Associations between arthritis and a broad range of psychiatric disorders: findings from a nationally representative sample. J Pain.
197 He Y, Zhang M, Lin EH, et al. (2008). Mental disorders among persons with arthritis: results from the World Mental Health Surveys. Psychol Med.
198 Brennenstuhl S, Shaked Y, Fuller-Thomson E. (2011). Suicide risk and cancer. Berman AL, Pompili M, editors. Medical conditions associated with suicide risk.
199 Kuo CJ, Chen VC, Lee WC, et al. (2010). Asthma and suicide mortality in young people: a 12-year follow-up study. Am J Psychiatry.
200 Goodwin RD, Marusic A. (2004). Asthma and suicidal ideation among youth in the community. Crisis.
201 Goodwin RD, Olfson M, Shea S, et al. (2003). Asthma and mental disorders in primary care. Gen Hosp Psychiatry.
202 Goodwin FK, Jamison KR. (2007). Manic-depressive illness: bipolar disorders and recurrent depression.
203 Rihmer Z, Angst J. (2005). Epidemiology of bipolar disorders. Kasper S, Hirschfeld RMA, editors. Handbook of bipolar disorders.
204 Abreu LN, Lafer B, Baca-Garcia E, Oquendo MA. (2009). Suicidal ideation and suicide attempts in bipolar disorders type I: an update for the clinician. Rev Bras Psiquiatr.
205 Rihmer Z. (2011). Depression and suicidal behavior. O’Connor R, Plat S, Gordon J, editors. International handbook of suicide prevention: research, policy, and practice.
206 Bolton JM, Pagura J, Enns MW, Grant B, Sareen J. (2010). A population-based longitudinal study of risk factors for suicide attempts in major depressive disorder. J Psychiatr Res.
207 Hawton K, Sutton L, Haw C, Sinclair J, Harriss L. (2005). Suicide and attempted suicide in bipolar disorders: a systematic review of risk factors. J Clin Psychiatry.
208 Hu G, Wilcox HC, Wissow L, Baker SP. (2008). Mid-life suicide: an increasing problem in U.S. Whites, 1999–2005. Am J Prev Med.
209 Kessler RC, Chiu WT, Demler O, Merikangas KR, Walters EE. (2005). Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry.
210 Sareen J, Cox BJ, Afifi TO, et al. (2005). Anxiety disorders and risk for suicidal ideation and suicide attempts: a population-based longitudinal study of adults. Arch Gen Psychiatry.
211 Nepon J, Belik SL, Bolton J, Sareen J. (2010). The relationship between anxiety disorders and suicide attempts: findings from the National Epidemiologic Survey on Alcohol and Related Conditions. Depress Anxiety.
212 Soloff PH, Lynch KG, Kelly TM, Malone KM, Mann JJ. (2000). Characteristics of suicide attempts of patients with major depressive episode and borderline personality disorder: a comparative study. Am J Psychiatry.
213 Paris J. (2011). Personality disorders and suicidal behavior. Connor RC, Platt S, Gordon J, editors. International handbook of suicide prevention: research, policy and prevention.
214 Paris J. (2003). Personality disorders over time.
215 Paris J. (2008). Clinical trials of treatment for personality disorders. Psychiatr Clin North Am.
216 Amador X. (2004). Understanding and assessing insight. Amador X, David A, editors. Insight and psychosis.
217 Hogarty GE, Flesher S, Ulrich R, et al. (2004). Cognitive enhancement therapy for schizophrenia: effects of a 2-year randomized trial on cognition and behavior. Arch Gen Psychiatry.
218 Centers for Disease Control and Prevention. Suicides due to alcohol and/or drug overdose: a data brief from the National Violent Death Reporting System.
219 Skog O-J. (1991). Alcohol and suicide—Durkheim revisited. Acta Sociol.
220 Conner KR, Duberstein PR. (2004). Predisposing and precipitating factors for suicide among alcoholics: empirical review and conceptual integration. Alcohol Clin Exp Res.
221 Mościcki EK. (2001). Epidemiology of completed and attempted suicide: toward a framework for prevention. Clin Neurosci Res.
222 Cherpitel CJ, Borges GL, Wilcox HC. (2004). Acute alcohol use and suicidal behavior: a review of the literature. Alcohol Clin Exp Res.
223 McKeon RT. (2009). Suicidal behavior.
224 Conner KR, Duberstein PR, Conwell Y. (1999). Age-related patterns of factors associated with completed suicide in men with alcohol dependence. Am J Addict.
225 Cheng AT. (1995). Mental illness and suicide. A case-control study in east Taiwan. Arch Gen Psychiatry.
226 Substance Abuse and Mental Health Services Administration. (2008). Substance abuse and suicide prevention: evidence & implications—a white paper.
227 Ilgen MA, Harris AH, Moos RH, Tiet QQ. (2007). Predictors of a suicide attempt one year after entry into substance use disorder treatment. Alcohol Clin Exp Res.
228 Wilcox HC, Conner KR, Caine ED. (2004). Association of alcohol and drug use disorders and completed suicide: an empirical review of cohort studies. Drug Alcohol Depend.
229 Mathy RM. (2002). Suicidality and sexual orientation in five continents: Asia, Australia, Europe, North America, and South America. Int J Sex Gend Stud.
230 King M, Semlyen J, Tai SS, et al. (2008). A systematic review of mental disorder, suicide, and deliberate self harm in lesbian, gay and bisexual people. BMC Psychiatry.
231 Grant JM, Mottet LA, Tanis J, Harrison J, Herman JL, Keisling M. (2011). Injustice at every turn: a report of the National Transgender Discrimination Survey.
232 Russell ST, Toomey RB. (2012). Men’s sexual orientation and suicide: evidence for U.S. adolescent-specific risk. Soc Sci Med.
233 Remafedi G. (2002). Suicidality in a venue-based sample of young men who have sex with men. J Adolesc Health.
234 Paul JP, Catania J, Pollack L, et al. (2002). Suicide attempts among gay and bisexual men: lifetime prevalence and antecedents. Am J Public Health.
235 Meyer IH, Dietrich J, Schwartz S. (2008). Lifetime prevalence of mental disorders and suicide attempts in diverse lesbian, gay, and bisexual populations. Am J Public Health.
236 Meyer IH. (2003). Prejudice, social stress, and mental health in lesbian, gay, and bisexual populations: conceptual issues and research evidence. Psychol Bull.
237 Hatzenbuehler ML, Keyes KM, Hasin DS. (2009). State-level policies and psychiatric morbidity in lesbian, gay, and bisexual populations. Am J Public Health.
238 Hatzenbuehler ML, McLaughlin KA, Keyes KM, Hasin DS. (2010). The impact of institutional discrimination on psychiatric disorders in lesbian, gay, and bisexual populations: a prospective study. Am J Public Health.
239 Ryan C, Russell ST, Huebner D, Diaz R, Sanchez J. (2010). Family acceptance in adolescence and the health of LGBT young adults. J Child Adolesc Psychiatr Nurs.
240 Blosnich JR, Bossarte RM, Silenzio VM. (2012). Suicidal ideation among sexual minority veterans: results from the 2005–2010 Massachusetts behavioral risk factor surveillance survey. Am J Public Health.
241 Movement Advancement Project (MAP). (2011). Talking about suicide & LGBT populations.
242 US Army Medical System and Materiel Command, Medical Mortality Surveillance Division. Armed Forces Medical Examiner System: Data reported as of May 26th, 2011.
243 U.S. Army. Army health promotion risk reduction suicide prevention report 2010.
244 U.S. Department of Defense. (2011). Department of Defense suicide event report (DoDSER): calendar year 2010 annual report.
245 Karch DL, Dahlberg LL, Patel N, et al. (2009). Surveillance for violent deaths—national violent death reporting system, 16 States, 2006. MMWR Surveill Summ.
246 Kaplan MS, Huguet N, McFarland BH, Newsom JT. (2007). Suicide among male veterans: a prospective population-based study. J Epidemiol Community Health.
247 Miller M, Barber C, Azrael D, Calle EE, Lawler E, Mukamal KJ. (2009). Suicide among U.S. veterans: a prospective study of 500,000 middle-aged and elderly men. Am J Epidemiol.
248 Veterans Health Administration. Administrative records and Internal briefings: Department of Veterans Affairs.
249 McCarthy JF, Valenstein M, Kim HM, Ilgen M, Zivin K, Blow FC. (2009). Suicide mortality among patients receiving care in the veterans health administration health system. Am J Epidemiol.
250 Ilgen MA, Bohnert AS, Ignacio RV, et al. (2010). Psychiatric diagnoses and risk of suicide in veterans. Arch Gen Psychiatry.
251 Watanabe KK, Kang HK. (1996). Mortality patterns among Vietnam veterans: a 24-year retrospective analysis. J Occup Environ Med.
252 Veterans Health Administration. (2008). Uniform mental health services in VA medical centers and clinics. Handbook 1160.01.
253 Hu G, Wilcox HC, Wissow L, Baker SP. (2008). Mid-life suicide: an increasing problem in U.S. Whites, 1999–2005. Am J Prev Med.
254 Caine ED, Knox KL, Conwell Y. (2011). Public health and population approaches for suicide prevention. Cohen NL, Galea S, editors. Population mental health: evidence, policy, & public health practice.
255 Knox K, Caine E. (2005). Establishing priorities for reducing suicide and its antecedents in the United States. Am J Public Health.
256 Oliffe JL, Phillips MJ. (2008). Men, depression and masculinities: A review and recommendations. J Mens Health.
257 Addis ME, Mahalik JR. (2003). Men, masculinity, and the contexts of help seeking. Am Psychol.
258 Conner KR, Cox C, Duberstein PR, Tian L, Nisbet PA, Conwell Y. (2001). Violence, alcohol, and completed suicide: a case-control study. Am J Psychiatry.
259 Barth A, Sogner L, Gnambs T, Kundi M, Reiner A, Winker R. (2011). Socioeconomic factors and suicide: An analysis of 18 industrialized countries for the years 1983 through 2007. J Occup Environ Med.
260 Knox K, Litts D, Talcott G, Feig J, Caine E. (2003). Risk of suicide and related adverse outcomes after exposure to a suicide prevention programme in the US Air Force: cohort study. BMJ.
261 Knox KL, Pflanz S, Talcott GW, et al. (2010). The US Air Force Suicide Prevention Program: implications for public health policy. Am J Public Health.
262 Gullestrup J, Lequertier B, Martin G. (2011). MATES in construction: impact of a multimodal, community-based program for suicide prevention in the construction industry. Int J of Environ Res Public Health.
263 Nakao M, Nishikitani M, Shima S, Yano E. (2007). A 2-year cohort study on the impact of an Employee Assistance Programme (EAP) on depression and suicidal thoughts in male Japanese workers. Int Arch Occup Environ Health.
264 Conwell Y, Duberstein PR, Connor K, Eberly S, Cox C, Caine ED. (2002). Access to firearms and risk for suicide in middle-aged and older adults. Am J Geriatr Psychiatry.
265 Mann JJ, Apter A, Bertolote J, et al. (2005). Suicide prevention strategies. JAMA.
266 Kellam SG, Brown CH, Poduska JM, et al. (2008). Effects of a universal classroom behavior management program in first and second grades on young adult behavioral, psychiatric, and social outcomes. Drug Alcohol Depend.
267 Conwell Y, Thompson C. (2008). Suicidal behavior in elders. Psychiatr Clin North Am.
268 Conwell Y, Duberstein PR, Cox C, Herrmann J, Forbes N, Caine ED. (1998). Age differences in behaviors leading to completed suicide. Am J Geriatr Psychiatry.