# Dedication

To those who have lost their lives by suicide,

To those who struggle with thoughts of suicide,

To those who have made an attempt on their lives,

To those caring for someone who struggles,

To those left behind after a death by suicide,

To those in recovery, and

To all those who work tirelessly to prevent suicide and suicide attempts in our nation.

We believe that we can and we will make a difference.