# National Strategy for Suicide Prevention Task Force

## Co-Leads

Regina Benjamin, M.D., M.B.A.

Surgeon General, Vice Admiral

U.S. Public Health Service

U.S. Department of Health and Human Services

Public Sector Co-Lead

Jerry Reed, Ph.D., M.S.W.

Vice President and Director

Suicide Prevention Resource Center

Education Development Center, Inc.

Private Sector Co-Lead

## Task Force Members

Carl Bell, M.D.

President and CEO

Community Mental Health Council

Director

Institute for Juvenile Research

Department of Psychiatry, School of Medicine

University of Illinois at Chicago

Derek Blumke

Cofounder and Former President

Student Veterans of America

Brian Boon, Ph.D.

President and CEO

Commission on Accreditation of Rehabilitation Facilities

Michael Botticelli, M.Ed.

Director

Bureau of Substance Abuse Services

Massachusetts Department of Public Health

Eric Caine, M.D.

Chair

Department of Psychiatry

University of Rochester Medical Center

Brian Dyak

President and CEO

Entertainment Industries Council, Inc.

James M. Galloway, M.D., F.A.C.P., F.A.C.C.

Assistant U.S. Surgeon General, USPHS

Regional Health Administrator

U.S. Department of Health and Human Services

Michael Hogan, Ph.D.

Commissioner

New York State Office of Mental Health

John (Jack) R. Jordan, Ph.D.

Founder and Director

Family Loss Project

Ira Katz, M.D., Ph.D.

Senior Consultant

U.S. Department of Veterans Affairs

Melvin A. Kohn, M.D., M.P.H.

Director and State Health Officer

Oregon Public Health Division

Oregon Health Authority

Richard McKeon, Ph.D., M.P.H.

Chief, Suicide Prevention Branch

Substance Abuse and Mental Health Services Administration

U.S. Department of Health and Human Services

Richard Ramsay, M.S.W., R.S.W.

Professor Emeritus of Social Work

University of Calgary, Canada

Daniel J. Reidenberg, Psy.D., F.A.P.A.

Executive Director

Suicide Awareness Voices of Education

Scott Ridgway, M.S.

Executive Director

Tennessee Suicide Prevention Network

Morton Silverman, M.D.

Senior Medical Advisor

Suicide Prevention Resource Center

Eduardo Vega, M.A.

Executive Director

Mental Health Association of San Francisco