# From the National Action Alliance for Suicide Prevention

As co-chairs of the National Action Alliance for Suicide Prevention (Action Alliance), we are honored to present this revised version of the National Strategy for Suicide Prevention.

This strategy recognizes that suicide is a complicated issue that requires equally complex solutions. Effective solutions need to incorporate multiple approaches at multiple levels. Effective prevention programs and policies stress the importance of wellness, resiliency, and protective factors; effective suicide response and intervention programs address risk factors, mental health and substance abuse services, and crisis response for those who are struggling with suicidal behaviors; and effective support programs are required for those who have been touched by suicide or suicidal behavior.

We believe that suicide is preventable when the right resources and services are in place. We also recognize that there is a lot of work to do to ensure that those who are most in need receive the services and support they require. It is our hope that this strategy will continue to guide suicide prevention efforts and save lives in communities across the United States.

The original National Strategy for Suicide Prevention called for the establishment of a public-private partnership to help guide the implementation of the goals and objectives recommended in the National Strategy. Launched in September 2010 by Health and Human Services Secretary Kathleen Sebelius and Defense Secretary Robert Gates, the Action Alliance is that partnership. The Action Alliance was established with a clear mission: to advance the National Strategy for Suicide Prevention by championing suicide prevention as a national priority, catalyzing efforts to implement high-priority objectives of the National Strategy, and cultivating the resources needed to sustain progress.

This report is the culmination of the efforts of the Action Alliance’s National Strategy Revision Task Force, co-led by Surgeon General Regina Benjamin and Jerry Reed, Director of the Suicide Prevention Resource Center. It represents the voice and input of countless individuals from across the country who provided thoughtful comments and feedback throughout the revision process.

The Action Alliance is committed to advancing the National Strategy for Suicide Prevention. We will continue to identify and advance high-priority objectives of the National Strategy that require leverage and coordination at the national level.

Thank you for your dedication to preventing suicide.

The Honorable John M. McHugh

Secretary of the Army

Public Sector Co-Chair

The Honorable Gordon H. Smith

President and CEO

National Association of Broadcasters

Private Sector Co-Chair