# From the National Council for Suicide Prevention

As the member organizations of the National Council for Suicide Prevention (NCSP), we are pleased to offer our support for the updated National Strategy for Suicide Prevention. We believe it will focus suicide prevention in our nation now and in the years ahead.

As a council composed of the leading national not-for-profit organizations dedicated to suicide prevention and to supporting survivors of suicide loss, we are grateful for the efforts to ensure that the new National Strategy was thoughtful, comprehensive, and included clear goals for reducing the incidence of suicide in America. We commend all those involved, specifically the National Strategy for Suicide Prevention Task Force, for carrying forward the excellent work started by former Surgeon General David Satcher and for leading this initiative to update and revise the National Strategy for Suicide Prevention.

Revising the National Strategy was no small task. It required the collective wisdom, expertise, and input from researchers and scientists, clinicians and health experts, those who have attempted suicide, and those who are bereaved by suicide, as well as many other stakeholders. It required input from multiple sectors—public, private, and nonprofit—as well as time and money. Ultimately, it required making difficult but important decisions regarding priorities for the future. We thank you for doing all of this, especially in light of the current economic climate.

The members of the NCSP are grateful for the opportunity to have served as advisors in the development of this document. After a decade of advancements in suicide prevention, we remain concerned that the nation is still in a period of rising suicide rates. Therefore, we believe that the timing for a revised National Strategy is right and that it offers an improved framework for achieving our ultimate goal of saving lives.

We also believe that the new National Strategy reflects the history of what we have learned about suicide prevention and advances our understanding of best approaches to reducing the incidence of suicide. Further, it will serve as a template for states, tribes, local communities, and public and private entities as they work to prevent suicide.

The NCSP stands ready to join our partners in the public and private sectors to fully implement the revised National Strategy. Through the collective expertise of the NCSP member organizations and through our willingness to collaborate with others, we remain dedicated to working aggressively to prevent further loss of life from suicide and to the improved health of all our citizens.

Respectfully submitted,

Alan L. Berman, Ph.D.

American Association of Suicidology

Alan Ross

Samaritans USA

Clark Flatt

The Jason Foundation

Dale Emme

Yellow Ribbon Suicide Prevention Program

Daniel J. Reidenberg, Psy.D.

Suicide Awareness Voices of Education

Donna Holland Barnes, Ph.D.

National Organization for People of Color Against Suicide

Phillip Satow

The Jed Foundation

Robert Gebbia

American Foundation for Suicide Prevention