# Appendix G Federal Working Group Agency Descriptions

## U.S. Department of Agriculture

Mission: To provide leadership on food, agriculture, natural resources, and related issues based on sound public policy, the best available science, and efficient management.

The U.S. Department of Agriculture (USDA) wants to be recognized as a dynamic organization that is able to efficiently provide the integrated program delivery needed to lead a rapidly evolving food and agriculture system.

USDA has created a strategic plan to implement its vision. The framework of this plan depends on these key activities: expanding markets for agricultural products and supporting international economic development; further developing alternative markets for agricultural products and activities; providing financing needed to help expand job opportunities and improve housing, utilities, and infrastructure in rural America; enhancing food safety by taking steps to reduce the prevalence of foodborne hazards from farm to table; improving nutrition and health by providing food assistance and nutrition education and promotion; and managing and protecting America’s public and private lands working cooperatively with other levels of government and the private sector.

### National Institute of Food and Agriculture

The National Institute of Food and Agriculture (NIFA) is an agency within USDA and part of the executive branch of the federal government. Congress created NIFA through the Food, Conservation, and Energy Act of 2008. NIFA’s unique mission is to advance knowledge for agriculture, the environment, human health and well-being, and communities by supporting research, education, and extension programs in the Land-Grant University System and other partner organizations.

For additional information:

U.S. Department of Agriculture

Web address: www.usda.gov

National Institute of Food and Agriculture

Web address: www.csrees.usda.gov

## U.S. Department of Defense

Mission: To provide the military forces needed to deter war and to protect the security of our country. The department’s headquarters is at the Pentagon.

The Department of Defense (DoD) is America’s oldest and largest government agency. With our military tracing its roots back to pre-Revolutionary War times, the DoD has grown and evolved with our nation.

Today, the department, headed by Secretary of Defense Leon E. Panetta, is not only in charge of the military, but it also employs a civilian force of thousands. With more than 1.4 million men and women on active duty and 718,000 civilian personnel, DoD is the nation’s largest employer. Another 1.1 million serve in the National Guard and Reserve forces. More than 2 million military retirees and their family members receive benefits.

Headquarters of the DoD, the Pentagon is one of the world’s largest office buildings. It is twice the size of the Merchandise Mart in Chicago, and has three times the floor space of the Empire State Building in New York. Built during the early years of World War II, it is still thought of as one of the most efficient office buildings in the world. Despite 17.5 miles of corridors it takes only seven minutes to walk between any two points in the building.

The nation’s security depends on its defense installations and facilities being in the right place, at the right time, with the right qualities and capacities to protect our national resources. Those resources have never been more important as America fights terrorists who plan and carry out attacks on U.S. facilities and the American people. U.S. military service members and civilians operate in every time zone and in every climate. More than 450,000 employees are overseas, both afloat and ashore.

DoD manages an inventory of installations and facilities to keep Americans safe. The department’s physical plant is huge by any standard, consisting of more than several hundred thousand individual buildings and structures located at more than 5,000 different locations or sites. When all sites are added together, DoD utilizes more than 30 million acres of land.

These sites range from the very small in size, such as unoccupied sites supporting a single navigational aid that sit on less than one-half acre, to the Army’s vast White Sands Missile Range in New Mexico, which occupies more than 3.6 million acres, or the Navy’s large complex of installations at Norfolk, Virginia, which includes more than 78,000 employees.

For additional information:

U.S. Department of Defense

Web address: www.defense.gov

## U.S. Department of Education

Mission: To promote student achievement and preparation for global competitiveness by fostering educational excellence and ensuring equal access.

The U.S. Department of Education (ED) was created in 1980 by combining offices from several federal agencies. ED’s 4,400 employees and $68 billion budget are dedicated to:

■ Establishing policies on federal financial aid for education, and distributing as well as monitoring those funds;
■ Collecting data on America’s schools and disseminating research;
■ Focusing national attention on key educational issues; and
■ Prohibiting discrimination and ensuring equal access to education.

### Office of Safe and Healthy Students

The Office of Safe and Healthy Students, a program office within the Office of Elementary and Secondary Education, administers, coordinates, and recommends policy for improving the quality and excellence of programs and activities that are designed to:

■ Provide financial assistance for: drug and violence prevention activities; activities that promote the health and well-being of students in elementary schools, secondary schools, and institutions of higher education; and school preparedness activities that contribute to improved conditions for learning. Activities may be carried out by other federal agencies, state and local educational agencies, and other public and private nonprofit organizations;
■ Participate in the formulation and development of ED program policy and legislative proposals and in overall administration policies related to violence and drug prevention; this includes drafting program regulations;
■ Participate in interagency committees, groups, and partnerships related to: drug and violence prevention, school preparedness, homeland security, missing and exploited youth, trafficked youth, and school health;
■ Participate with other federal agencies in the development of a national research and data collection agenda for drug and violence prevention and preparedness; and
■ Administer the department’s programs relating to citizenship and civics education.

For additional information:

U.S. Department of Education

Web address: www.ed.gov

## U.S. Department of Health and Human Services

Mission: The mission of the Department of Health and Human Services (HHS) is to enhance the health and well-being of Americans by providing for effective health and human services and by fostering strong, sustained advances in the sciences, underlying medicine, public health, and social services.

HHS is the government’s principal agency for protecting the health of all Americans and providing essential human services, especially for those who are least able to help themselves. HHS represents almost a quarter of all federal outlays, and it administers more grant dollars than all other federal agencies combined. HHS’s Medicare program is the nation’s largest health insurer, handling more than 1 billion claims per year. Medicare and Medicaid together provide health care insurance for one in four Americans.

HHS works closely with state and local governments, and many HHS-funded services are provided at the local level by state or county agencies or through private sector grantees. The department’s programs are administered by 11 operating divisions, including eight agencies in the U.S. Public Health Service and three human services agencies. The department includes more than 300 programs, covering a wide spectrum of activities. In addition to the services they deliver, HHS programs provide for equitable treatment of beneficiaries nationwide, and they enable the collection of national health and other data.

Departmental leadership is provided by the Office of the Secretary. Also included in the department is the Office of Public Health and Science, the Office of the HHS Inspector General, and the HHS Office for Civil Rights. In addition, the Program Support Center, a self-supporting division of HHS, provides administrative services for HHS and other federal agencies.

For additional information:

U.S. Department of Health and Human Services

Web address: www.hhs.gov

## Administration on Aging

Mission: To develop a comprehensive, coordinated, and cost-effective system of home and community-based services that helps elderly individuals maintain their health and independence in their homes and communities. To achieve this mission, the Administration on Aging (AoA) works with states and communities to enhance the availability of effective and coordinated services that are responsive to the needs and preferences of older persons, persons with disabilities, and their family caregivers.

AoA was established in 1965 with the passage of the Older Americans Act and is charged with advancing the concerns and interests of older people, persons with disabilities, and their family caregivers. To accomplish this vision, AoA administers a combination of competitive and formula grants that support the development, delivery, and evaluation of supportive services through the Aging Network, which consists of 56 State Units on Aging, 629 Area Agencies on Aging, 256 Tribal and Native organizations, 20,000 service providers, and thousands of volunteers. By leveraging public and private resources and partnerships, the Aging Network delivers streamlined access to a robust menu of supports, including long-term care services, nutrition programs, preventive health services, family caregiver programs, care transitions interventions, and supports that prevent elder abuse and promote elder rights.

Physical illness, emotional issues, and functional impairment are common risk factors for suicide among older adults. Through AoA’s evidence-based health, dementia, and wellness programs, the Aging Network is developing a national system of effective programs, including depression care and suicide prevention programs, that help older adults, persons with disabilities, and their family caregivers maintain their health and independence. AoA envisions the continuation of a vibrant, integrated system that provides access to person-centered supportive services that promote physical and emotional well-being. AoA has recently become a part of the Administration for Community Living.

For additional information:

Administration on Aging

Web address: www.aoa.gov

## Agency for Health Care Research and Quality

Mission: To improve the quality, safety, efficiency, and effectiveness of health care for all Americans. As 1 of 12 agencies within HHS, the Agency for Health Care Research and Quality (AHRQ) supports research that helps individuals make more informed decisions and improves the quality of health care services. AHRQ was formerly known as the Agency for Health Care Policy and Research.

AHRQ is committed to improving care safety and quality by developing successful partnerships and generating the knowledge and tools required for long-term improvement. The goal of its research is measurable improvements in health care in America, gauged in terms of improved quality of life and patient outcomes, lives saved, and value gained for what AHRQ spends.

To achieve its goals, the agency is committed to organizational excellence, the use of efficient and responsive business processes to maximize the agency’s resources, and the effectiveness of its programs. The agency’s overall focus is:

■ Safety and quality: Reduce the risk of harm by promoting delivery of the best possible health care;
■ Effectiveness: Improve health care outcomes by encouraging the use of evidence to make informed health care decisions; and
■ Efficiency: Transform research into practice to facilitate wider access to effective health care services and reduce unnecessary costs.

AHRQ’s customers include:

■ Clinicians and other health care providers, such as hospitals;
■ Consumers and patients;
■ Health care policymakers at the federal, state, and local levels;
■ Purchasers and payers, such as employers and public and private insurers; and
■ Other health officials, such as hospital systems and medical school faculty.

For additional information:

Agency for Health Care Research and Quality

Web address: www.ahrq.gov

## Centers for Disease Control and Prevention

Mission: Collaborate to create the expertise, information, and tools that individuals and communities need to protect their health—through health promotion, prevention of disease, injury and disability, and preparedness for new health threats.

The Centers for Disease Control and Prevention (CDC), a part of HHS, is the primary federal agency for conducting and supporting public health activities in the U.S. Through its centers, institutes, and offices, CDC works with partners throughout the nation and the world to monitor health, detect and investigate health problems, develop and advocate sound public health policies, implement prevention strategies, promote healthy behaviors, foster safe and healthful environments, and provide leadership and training.

CDC suicide prevention activities include efforts in the National Center for Health Statistics, National Center for Chronic Disease Prevention and Health Promotion, and National Center for Injury Prevention and Control. CDC maintains national data on suicides, conducts the Youth Risk Behavior Survey, and publishes reports on self-directed injury at all levels. Additional examples of CDC activities include promoting collaborations in specific communities for suicide prevention and conducting research on suicidal behavior and program evaluation.

For additional information:

Centers for Disease Control and Prevention

Web address: www.cdc.gov

National Injury Center’s Division of Violence Prevention

Web address: www.cdc.gov/violenceprevention

## Health Resources and Services Administration

Mission: To improve health and achieve health equity through access to quality services, a skilled health workforce and innovative programs.

Health Resources and Services Administration (HRSA) is the primary federal agency for improving access to health care services for people who are uninsured, isolated, or medically vulnerable. Tens of millions of Americans get affordable health care and other help through HRSA’s 100-plus programs and more than 3,000 grantees.

Comprising six bureaus and 10 offices, HRSA provides leadership and financial support to health care providers in every state and U.S. territory. HRSA grantees provide health care to uninsured people, people living with HIV/AIDS, and pregnant women, mothers, and children. They train health professionals and improve systems of care in rural communities.

HRSA oversees organ, bone marrow, and cord blood donation. It supports programs that prepare against bioterrorism, compensates individuals harmed by vaccination, and maintains databases that protect against health care malpractice and health care waste, fraud, and abuse.

Since 1943, the agencies that were HRSA precursors have worked to improve the health of needy people. HRSA was created in 1982, when the Health Resources Administration and the Health Services Administration were merged.

For additional information:

Health Resources and Services Administration

Web address: www.hrsa.gov

## Indian Health Service

Mission: To raise the physical, mental, social, and spiritual health of American Indians and Alaska Natives (AI/AN) to the highest level. The goal is to assure that comprehensive, culturally acceptable personal and public health services are available and accessible to AI/AN people.

The Indian Health Service (IHS) is the principal federal health care provider and health advocate for Indian people. IHS provides a comprehensive health service delivery system for approximately 2 million American Indians and Alaska Natives who belong to 566 federally recognized tribes in 36 states.

Within IHS, the Behavioral Health Division’s mission is to instill balance, wellness, and resilience throughout AI/AN communities in partnership with tribes, tribal organizations, and urban Indian health organizations, as well as with federal, state, and local agencies. The division seeks to foster excellence in holistic approaches that promote healthy lifestyles, families, and communities. The division will coordinate national efforts to build capacity and share knowledge throughout Indian Country and will assist in the development, implementation, and evaluation of culture- and community-based programming.

Suicide Prevention: The IHS Suicide Prevention Initiative has provided a crucial framework and coordination capability to maximize available resources for addressing the tragedy of suicide in AI/AN communities. This initiative builds on the foundation of HHS’s National Strategy for Suicide Prevention and the 11 goals and 68 objectives for the nation to reduce suicidal behavior and its consequences, while ensuring to honor and respect AI/AN traditions and practices.

IHS has five targeted approaches for suicide prevention and intervention: (1) Assist IHS, tribal, and urban Indian programs and communities in addressing suicide utilizing community level cultural approaches; (2) Identify and share information on best and promising practices; (3) Improve access to behavioral health services; (4) Strengthen and enhance IHS epidemiological capabilities; and (5) Promote collaboration between tribal and urban Indian communities with federal, state, and local community agencies.

The Methamphetamine and Suicide Prevention Initiative (MSPI) is a nationally coordinated program providing targeted methamphetamine and suicide prevention and intervention services. This initiative promotes the development of evidence-based and promising practices that are culturally appropriate prevention and treatment approaches to methamphetamine abuse and suicidal behaviors in a community-driven context. MSPI now supports 125 community developed prevention and intervention pilot programs across the country.

IHS maintains the IHS Community Suicide Prevention website to share information on best and promising practices nationally. The website provides culturally appropriate information about best and promising suicide prevention and early intervention programs and training opportunities.

For additional information:

Indian Health Service

Web address: www.ihs.gov/index.cfm

IHS American Indian and Alaska Native Suicide Prevention Website

Web address: www.ihs.gov/NonMedicalPrograms/nspn

## National Institute of Mental Health

Mission: To transform the understanding and treatment of mental illnesses through basic and clinical research, paving the way for prevention, recovery, and cure.

The National Institute of Mental Health (NIMH) was formally established in 1949 by Congress through the National Mental Health Act to establish a biomedical and behavioral research program to study individual, social, and economic problems of people with mentally illness in the United States. Over the past 60 years, NIMH research initiatives have evolved to include health services, research training, and health information dissemination with respect to the cause, diagnosis, treatment, control, and prevention of mental illness. To accomplish its work, NIMH administers several types of competitive grant programs, including research project grants, center grants, career awards, fellowships and training grants, and contracts. NIMH also supports the development of research resources that will help stimulate work in this field.

Current NIMH suicide prevention activities focus on multiple projects designed to develop the next generation of suicide prevention strategies. One notable activity is NIMH’s partnership with the Department of the Army to conduct the Army Study to Assess Risk and Resilience in Service Members Project—the largest study of mental health risk and resilience ever conducted among military personnel. This project, a cooperative agreement led scientifically by NIMH, specifically looks to identify and understand factors related to risk for suicide among Army soldiers. The results will contribute significantly to our understanding of risk and resilience associated with suicide, both within the Army and among the broader adult population.

NIMH also has a lead role with the National Action Alliance for Suicide Prevention (Action Alliance), a public-private partnership tasked with developing the next National Strategy for Suicide Prevention. Alongside The Jed Foundation, NIMH is cochairing the Action Alliance’s Research Task Force (RTF), which is developing a research agenda to reduce suicide morbidity (attempts) and mortality (deaths) by at least 20 percent in 5 years, and 40 percent or more in 10 years. To develop this agenda, RTF is reviewing public and private research portfolios, performing a targeted review of the research literature, statistically simulating the effects of potential interventions, and gathering input from more than 700 stakeholders through a multistage survey process. RTF’s national research agenda will be structured around a set of short- and long-term strategic goals that address key issues in suicide prevention.

For additional information:

National Institute of Mental Health

Web address: www.nimh.nih.gov

## Substance Abuse and Mental Health Services Administration

Mission: To reduce the impact of substance abuse and mental illness on America’s communities. In order to achieve this mission, the Substance Abuse and Mental Health Services Administration (SAMHSA) has identified eight strategic initiatives to focus the agency’s work on improving lives and capitalizing on emerging opportunities.

SAMHSA was established in 1992 and directed by Congress to target effectively substance abuse and mental health services to the people most in need and to translate research in these areas more effectively and more rapidly into the general health care system. Over the years, SAMHSA has demonstrated that prevention works, treatment is effective, and people recover from mental and substance use disorders. Behavioral health services improve health status and reduce health care and other costs to society. Continued improvement in the delivery and financing of prevention, treatment, and recovery support services provides a cost-effective opportunity to advance and protect the nation’s health. To accomplish its work, SAMHSA administers a combination of competitive, formula, and block grant programs and data collection activities.

Suicide prevention activities of the Center for Mental Health Services (CMHS) within SAMHSA center on initiating national grant programs to implement and evaluate suicide prevention activities. CMHS is involved in developing suicide prevention guidelines for use in our nation’s schools as well as supporting efforts to identify those children at greatest risk of suicide. In addition, SAMHSA sponsors conferences, workshops, and meetings to further national goals for suicide prevention. SAMHSA sponsors the National Suicide Prevention Lifeline, a national network of more than 150 crisis centers that are available to respond to those in emotional distress and their families and friends. SAMHSA also supports the Suicide Prevention Resource Center, which provides prevention support, training, and resources to assist organizations and individuals to develop suicide prevention programs, interventions and policies, and to advance the National Strategy for Suicide Prevention.

For additional information:

Substance Abuse and Mental Health Services Administration

Web address: www.samhsa.gov

Center for Mental Health Services

Web address: www.samhsa.gov/about/cmhs.aspx

## U.S. Department of Veterans Affairs

Mission: To fulfill President Abraham Lincoln’s promise, “To care for him who shall have borne the battle, and for his widow, and his orphan,” by serving and honoring the men and women who are America’s veterans.

Although the Department of Veterans Affairs (VA) can trace its history back to the Revolutionary War, it became a cabinet-level Department in 1989. It includes three administrations: the Veterans Health Administration (VHA), the Veterans Benefits Administration (VBA), and the National Cemetery Administration (NCA). These administrations coordinate services for more than 22 million Americans who are veterans. As of the end of 2010, more than 8 million veterans were enrolled in VHA, and more than 4 million veterans and survivors received VBA compensation and pension benefits. VHA provides patient-centered health care in 153 medical centers, 974 outpatient clinics, 288 Vet Centers, 98 residential care facilities, and 133 Community Living Centers that provide nursing home services. Approximately 6 million patients are treated during the year through more than 75 million outpatient visits. Altogether, VHA is the nation’s largest integrated health care system. It functions in close collaboration with DoD to support returning veterans in their transition from active duty to their communities, and with a network of academic affiliates to facilitate interactions with other systems and providers of health care.

VA’s activities in suicide prevention include outreach and public information, clinical services, education, and research. The Office of Suicide Prevention was established in 2007 as a part of VA’s enhancement of its mental health programs to coordinate a program built on the principles that suicide prevention requires public health activities, ready access to high-quality mental health services, and clinical programs that specifically target individuals at high risk. The program centers around a call center linked with the SAMHSA-supported National Suicide Prevention Lifeline, suicide prevention coordinators in each of VHA’s medical centers, and a structured public messaging campaign. The program also includes two centers of excellence that conduct research, provide education, and develop new clinical programs, one focused on clinical care, and the other on public health strategies.

For additional Information:

Department of Veterans Affairs

Web address: www.va.gov

VA’s Suicide Prevention Program

Web address: www.mentalhealth.va.gov/suicide_prevention