# Appendix E General Suicide Prevention Resources

This appendix contains selected reports, guidelines, and other key resources on general aspects of suicide prevention. It also includes descriptions of federal agencies and national organizations that focus on suicide prevention. These groups can often provide program materials, trainings, and other resources. For information and resources for specific groups at increased risk for suicide, see Appendix D.

## Suicide Prevention National Strategy Documents

### United States

#### National Strategy for Suicide Prevention

National Action Alliance for Suicide Prevention

www.surgeongeneral.gov/library/reports/national-strategy-suicide-prevention/index.html

www.actionallianceforsuicideprevention.org/NSSP

www.samhsa.gov/nssp

The National Strategy for Suicide Prevention provides the framework for suicide prevention for the United States. First published in 2001 and then updated in 2012, the National Strategy represents the combined work of advocates, clinicians, researchers, survivors, and others. It lays a framework for action to prevent suicide and guides the development of an array of services and programs.

#### Charting the Future of Suicide Prevention: A 2010 Progress Review of the National Strategy and Recommendations for the Decade Ahead, 2010

Education Development Center, Inc.

www.sprc.org/library/ChartingTheFuture_Fullbook.pdf

This report reviews developments in the field of suicide prevention in the 9 years following the publication of the National Strategy for Suicide Prevention. It identifies the areas of most important progress, as well as crucial areas that have gone relatively unaddressed. It also explores new issues and initiatives that have emerged to claim attention or offer solutions.

#### Reducing Suicide: A National Imperative, 2002

Institute of Medicine

http://www.nap.edu/openbook.php?isbn=0309083214

This Institute of Medicine report, commissioned by several federal agencies, summarizes the state of the science base, gaps in knowledge, strategies for prevention, and research designs for the study of suicide.

### Australia

#### Living Is for Everyone (LIFE) Framework, 2007

Australian Government Department of Health and Ageing Commonwealth of Australia, Canberra http://www.livingisforeveryone.com.au/Home.html

### England

#### Consultation on Preventing Suicide in England: A Cross-Government Outcomes Strategy to Save Lives, 2011

United Kingdom Department of Health

www.dh.gov.uk/en/Consultations/Liveconsultations/DH_128065

This document proposes a new suicide prevention strategy for England.

### Ireland

#### Reach Out: Irish National Strategy for Action on Suicide Prevention 2005–2014

National Office for Suicide Prevention, Ireland

www.nosp.ie/reach_out.pdf

### New Zealand

#### New Zealand Suicide Prevention Action Plan 2008–2012: The Evidence for Action

Ministry of Health, Wellington, New Zealand

www.spinz.org.nz/file/downloads/pdf/file_48.pdf

### Norway

#### National Plan for Suicide Prevention 1994–1998, 1999

Norwegian Health Board

www.med.uio.no/klinmed/english/research/centres/nssf/articles/prevention/The_national_plan_for_suicide_prevention_1994-1998.pdf

#### The Norwegian Plan for Suicide Prevention Follow-up Project 2000–2002: Building on Positive Experiences, 2001

Norwegian Journal Suicidologi, no. 1

www.med.uio.no/klinmed/english/research/centres/nssf/articles/prevention/MehlumAndReinholdt.pdf

### Scotland

#### Refreshing the National Strategy and Action Plan to Prevent Suicide in Scotland: Report of the National Suicide Prevention Working Group, 2010

The Scottish Government

www.scotland.gov.uk/Publications/2010/10/26112102/0

This report describes the revised Scottish national strategy for suicide prevention.

## Media Reporting on Suicide

### Picture This: Depression and Suicide Prevention, 2009

www.eiconline.org/resources/publications/z_picturethis/Disorder.pdf

This is a guide for content creators in the entertainment industry that addresses issues within the areas of depression and suicide prevention. These issues include those as identified by mental health experts, advocates, policymakers, and others working to improve public awareness about and reduce instances of depression and suicide.

### Recommendations for Reporting on Suicide, 2011

Substance Abuse and Mental Health Services Administration (SAMHSA), U. S. Department of Health and Human Services (HHS)

www.reportingonsuicide.org

This website presents research-based recommendations for reporting on suicide, including suggestions for online media, message boards, bloggers, and “citizen journalists.”

## Evidence-Based and Best Practices for Suicide Prevention

### Best Practices Registry for Suicide Prevention

Suicide Prevention Resource Center (SPRC) and American Foundation for Suicide Prevention (AFSP)

www.sprc.org/bpr

This registry contains approximately 100 suicide prevention programs, including student curricula and peer leader programs, gatekeeper trainings, and trainings for health and mental health professionals. The registry is organized into three sections. Section I: Evidence-Based Programs lists interventions that have undergone evaluation and demonstrated positive outcomes. Most of these are the suicide prevention programs in SAMHSA’s National Registry of Evidence-Based Programs and Practices (NREPP). Section II: Expert and Consensus Statements lists statements that summarize the current knowledge in the suicide prevention field and provide best practice recommendations to guide program and policy development. Section III: Adherence to Standards lists suicide prevention programs and practices whose content has been reviewed for accuracy, likelihood of meeting objectives, and adherence to program design standards.

### National Registry of Evidence-Based Programs and Practices

SAMHSA, HHS

www.nrepp.samhsa.gov

NREPP is a searchable online registry of roughly 230 interventions supporting mental health promotion, substance abuse prevention, and mental health and substance abuse treatment. It includes a small number of interventions focused on suicide prevention and treatment. The registry connects members of the public to intervention developers so that they can learn how to implement these approaches in their communities.

## Suicide Data and Surveillance

### National Violent Death Reporting System (NVDRS)

Centers for Disease Control and Prevention (CDC), HHS

www.cdc.gov/injury/wisqars/nvdrs.html

NVDRS is a surveillance system that links data from law enforcement, coroners and medical examiners, vital statistics, and crime laboratories to assist each participating state in designing and implementing tailored prevention and intervention efforts, including for suicide. NVDRS also pools these data to better depict the scope and nature of violence.

### Self-Directed Violence Surveillance: Uniform Definitions and Recommended Data Elements, Version 1.0, 2011

National Center for Injury Prevention and Control, CDC, HHS

www.cdc.gov/ViolencePrevention/pub/selfdirected_violence.html

To address the current lack of a uniform definition on fatal and nonfatal self-harm, CDC developed this resource to improve understanding of self-directed violence and standardize data collection. The definitions and data elements were developed in collaboration with the U.S. Department of Veterans Affairs and the U.S. Department of Defense.

### Suicide Prevention Data Reports

Office of Applied Studies, SAMHSA, HHS

www.oas.samhsa.gov/suicide.cfm

This website lists reports that provide surveillance data on suicidal thoughts and behaviors.

### Web-Based Injury Statistics Query and Reporting System (WISQARS)

CDC, HHS

www.cdc.gov/injury/wisqars

This is an interactive database system that provides customized reports of data from a variety of sources on fatal and nonfatal injuries, violent deaths, and cost of injury. The system features a large amount of data on suicide.

### Suicidal Thoughts and Behaviors Among Adults

www.oas.samhsa.gov/2k9/165/Suicide.htm

This issue of The National Survey on Drug Use and Health Report examines suicidal thoughts and behaviors among adults aged 18 and older. Data are presented by age group, gender, and past year substance use disorder. All findings in the report are based on 2008 data.

## Suicide Prevention Organizations

For organizations that focus on specific groups with increased suicide risk, see Appendix D.

### American Association of Suicidology (AAS)

www.suicidology.org

AAS promotes research, public awareness programs, public education, and training for professionals and volunteers. It serves as a national clearinghouse for information on suicide, publishing and disseminating statistics and suicide prevention resources. AAS also hosts annual national conferences for professionals and survivors.

### American Foundation for Suicide Prevention (AFSP)

www.afsp.org

AFSP funds research and offers educational programs and resources for professionals, survivors of suicide loss, and the public. With SPRC, AFSP coproduces the Best Practices Registry (BPR) for Suicide Prevention. AFSP’s Public Policy Division, SPAN USA, promotes and keeps track of policies and legislation related to suicide prevention. AFSP chapters provide connections to local resources and services addressing suicide prevention. The chapters also organize awareness events.

### International Association for Suicide Prevention (IASP)

www.iasp.info

IASP is an international suicide prevention membership organization dedicated to preventing suicidal behavior, alleviating its effects, and providing a forum for academics, mental health professionals, crisis workers, volunteers, and suicide survivors. IASP sponsors World Suicide Prevention Day, congresses, task forces, conferences, and awards for research in suicidology.

### Jason Foundation

www.jasonfoundation.com

The Jason Foundation is an educational organization dedicated to the awareness and prevention of youth suicide. It produces educational curricula and training programs for students, educators, youth workers, and parents to help them identify and assist at-risk youth.

### Means Matter, Harvard School of Public Health

www.hsph.harvard.edu/means-matter

The mission of the Means Matter campaign is to increase the proportion of suicide prevention groups that promote activities that reduce a suicidal person’s access to lethal means of suicide. The website has a wide variety of information to help families, clinicians, suicide prevention groups, local communities, and colleges and universities.

### National Council for Suicide Prevention (NCSP)

www.ncsponline.org

NCSP is a group of leading national suicide prevention organizations that comes together to speak as a collective voice on selected issues and is dedicated to advancing suicide prevention through leadership and advocacy. NCSP philosophy is rooted in the belief that collaboration between like organizations will help pool resources and strengthen member organizations’ ability to effect positive change in the field.

### National Organization for People of Color Against Suicide (NOPCAS)

www.nopcas.org

NOPCAS addresses suicide prevention, intervention, and postvention in communities of color. NOPCAS provides professional development and culturally appropriate training for lay and professional audiences as well as sponsoring survivor/bereavement support groups. It also provides the online crisis intervention network entitled “I’m Alive,” staffed by certified volunteers, and a speakers bureau.

### National Suicide Prevention Lifeline (Lifeline)

www.suicidepreventionlifeline.org

The Lifeline provides immediate assistance 24 hours a day, 7 days a week to individuals in suicidal crisis by connecting them to the nearest available suicide prevention and mental health service provider through a toll-free telephone number: 1–800–273–TALK (8255). The Lifeline also provides informational materials featuring the phone number, such as brochures, wallet cards, and posters.

### Samaritans USA

www.samaritansusa.org

Samaritans USA provides services to those at risk for suicide, provides support for those who have experienced a loss due to suicide, and educates caregivers and health providers. Crisis lines are the cornerstone of Samaritans USA’s services. Samaritans USA also provides suicide prevention education to the public and survivor support groups.

### Suicide Awareness Voices of Education (SAVE)

www.save.org

SAVE’s mission is to prevent suicide through public awareness and education, reduce prejudice, and serve as a resource for those touched by suicide. SAVE’s prevention and education programs are designed to increase awareness and knowledge about brain illnesses and suicide, accessing community resources, and understanding and use of intervention skills to help prevent suicide.

### Suicide Prevention Resource Center (SPRC)

www.sprc.org

SPRC is a SAMHSA-funded, national center that helps strengthen the efforts of state, tribal, community, and campus suicide prevention organizations and coalitions and organizations that serve populations with high suicide rates. It provides technical assistance, training, a variety of resource materials, a current awareness newsletter (The Weekly SPARK), and a searchable online library. In partnership with AFSP, SPRC coproduces the BPR for Suicide Prevention. SPRC also provides organizational support for the National Action Alliance for Suicide Prevention.

### The Jed Foundation

www.jedfoundation.org

The Jed Foundation works to promote emotional health and prevent suicide among college and university students. The Jed Foundation’s programs include: ULifeline, an online resource that gives students access to campus-specific resources and allows them to take an anonymous mental health screening; the Half of Us campaign with mtvU, which uses online, on-air, and on campus programming to encourage help-seeking; Love is Louder, a movement online and in communities to build connectedness and increase resiliency; and more.

### The Link Counseling Center

www.thelink.org

The Link provides services and support to those who have lost a loved one to suicide, including workshops, resource materials, telephone counseling, information, and referrals. The Link also offers trainings for survivors and professionals on creating and facilitating support groups for survivors.

### Yellow Ribbon

www.yellowribbon.org

Yellow Ribbon is the producer of the adult gatekeeper training Be a Link!, and the youth program Ask 4 Help! Its services include providing technical assistance to states and communities and support to survivors, including a list of survivor support groups across the United States.

## U.S. Government Agencies

Information on the federal agencies that are a part of the Federal Working Group on Suicide Prevention is provided in Appendix G. These agencies include the National Institute of Mental Health (NIMH), within the National Institutes of Health (NIH). The following two other NIH institutes also address issues related to suicide prevention.

### National Institute on Alcohol Abuse and Alcoholism (NIAAA), NIH, HHS

www.niaaa.nih.gov

NIAAA provides leadership in the national effort to reduce alcohol-related problems. Alcohol is a significant risk factor for suicide, and NIAAA publishes studies on how alcohol use interacts with conditions such as depression and stress to contribute to suicide. NIAAA also provides data on alcohol involvement in suicide.

### National Institute on Drug Abuse (NIDA), NIH, HHS

www.nida.nih.gov

NIDA funds and publishes studies on the effects of substance abuse on mental health, including suicide, and hosts Suicide Studies Lectures, which review current standards to define, classify, assess, and treat suicide-related disorders that sometimes play a role in drug abuse and addiction. NIDA also sponsored the landmark workshop Drug Abuse and Suicidal Behavior.