# Appendix B Crosswalk of Goals and Objectives From 2001 to 2012

This appendix describes how the goals and objectives included in the 2001 National Strategy for Suicide Prevention (National Strategy) are addressed in the 2012 National Strategy. As noted in the Introduction, the goals and objectives have been updated, revised, and, in some cases, replaced to reflect advances in knowledge and areas where the proposed actions have been completed. For more information on the organization of the 2012 goals and objectives, see the Introduction section. For a list of the 2012 goals and objectives, see Appendix A.

GOAL OR OBJECTIVE | | | Notes
2001 | | 2012 | Notes
Goal 1 | Increase awareness that suicide is a public health problem that is preventable. | Goal 2 | The goal was expanded to address a broad range of communication efforts targeting various audiences.
1.1 | Increase the number of states in which public information campaigns designed to increase public knowledge of suicide prevention reach at least 50 percent of the state’s population. | 2.1 and 2.4 | The objective was expanded to focus on changing the knowledge, attitudes, and behaviors of various audiences.
1.2 | Establish regular national congresses on suicide prevention designed to foster collaboration with stakeholders on prevention strategies across disciplines and with the public. | 1.1 | The objective was revised to encourage the integration of suicide prevention into the values, culture, leadership, and work of a wide range of organizations and programs.
1.3 | Convene national forums on issues likely to strongly influence effectiveness of suicide prevention messages. | N/A | Several organizations dedicated to suicide prevention conduct national meetings on a regular basis.
1.4 | Increase the number of public and private institutions active in suicide prevention that are involved in collaborative dissemination of information on the World Wide Web. | 2.3 and 4.3 | The objective was modified to support an increase in all types of online communication efforts. The related Objective 4.3 focuses on guidelines addressing the safety of online content.
Goal 2 | Develop broad-based support for suicide prevention. | Goal 1 | The wording was revised: “Integrate and coordinate suicide prevention activities across multiple sectors and settings.”
2.1 | Expand Federal Steering Group (FSG) to improve federal coordination, help implement the NSSP, and coordinate future revisions. | Achieved and 1.3 | The FSG was expanded and is now called the Federal Working Group. The objective was revised to focus on sustaining and strengthening federal collaborations.
2.2 | By 2002, establish public-private partnerships to advance and coordinate implementation of NSSP. | Achieved at national level and 1.4 | The partnership was formed as the National Action Alliance for Suicide Prevention. The objective was expanded to support similar efforts at the state/territorial, tribal, and local levels.
2.3 | Increase the number of national professional, voluntary, and other groups that integrate suicide prevention into ongoing programs and activities. | 1.1 | The objective now addresses the integration of suicide prevention into the values, culture, leadership, and work of a wide range of organizations and programs with a role to support suicide prevention activities.
2.4 | Increase the number of nationally organized faith communities adopting institutional policies promoting suicide prevention. | 1.1 | (see above)
Goal 3 | Goal 3: Develop and implement strategies to reduce the stigma associated with being a consumer of mental health, substance abuse, and suicide prevention services. | Goal 3 and 3.2 | The focus of the goal was broadened to promote greater knowledge of protective factors and of factors that promote wellness and recovery. Reducing prejudice and discrimination is addressed in Objective 3.2.
3.1 | By 2005, increase the proportion of the public that views mental and physical health as equal and inseparable components of overall health. | 3.2 | Addressed in Objective 3.2, which focuses on reducing the prejudice and discrimination associated with suicide and suicide-related behaviors.
3.2 | By 2005, increase the proportion of the public that views mental disorders as real illnesses that respond to specific treatments. | 3.2 and 3.3 | (see above) Also addressed in Objective 3.3, which focuses on promoting the understanding that recovery from mental and substance use disorders is possible.
3.3 | By 2005, increase the proportion of the public that views consumers of mental health, substance abuse, and suicide prevention services as pursuing fundamental care and treatment for overall health. | 3.2 and 3.3 | (see above)
3.4 | By 2005, increase the proportion of those suicidal persons with underlying disorders who receive appropriate mental health treatment. | 8.3 | The new Objective 8.3 promotes timely access to assessment, intervention, and effective care for individuals with a heightened risk for suicide.
Goal 4 | Develop and implement community-based suicide prevention programs. | Goal 5 | The revised goal addresses the development, implementation, and monitoring of programs that promote wellness and prevent suicide and related behaviors.
4.1 | By 2005, increase the proportion of states with comprehensive suicide prevention plans that a.) coordinate across government agencies, b.) involve the private sector, and c.) support plan development, implementation, and evaluation in their communities. | 5.1 | Nearly all states have a suicide prevention plan, but there is much variation among plans. Objective 5.1 supports improvements to the plans.
4.2 | By 2005, increase the proportion of school districts and private school associations with evidence-based programs designed to address serious childhood and adolescent distress and prevent suicide. | 5.2 | The new Objective 5.2 includes programs conducted in various settings, including schools, which were previously addressed in separate objectives.
4.3 | By 2005, increase the proportion of colleges and universities with evidence-based programs designed to address serious young adult distress and prevent suicide. | 5.2 | (see above)
4.4 | By 2005, increase the proportion of employers that ensure the availability of evidence-based prevention strategies for suicide. | 5.2 | (see above)
4.5 | By 2005, increase the proportion of correctional institutions, jails, and detention centers housing either adult or juvenile offenders with evidence-based suicide prevention programs. | 5.2 | (see above)
4.6 | By 2005, increase the proportion of state aging networks that have evidence-based suicide prevention programs designed to identify and refer for treatment of elderly people at risk for suicidal behavior. | 5.2 | (see above)
4.7 | By 2005, increase the proportion of family, youth, and community service providers and organizations with evidence-based suicide prevention programs. | 5.2 | (see above)
4.8 | By 2005, develop one or more training and technical resource centers to build capacity for states and communities to implement and evaluate suicide prevention programs. | Achieved | The Suicide Prevention Resource Center was established in 2002.
Goal 5 | Promote efforts to reduce access to lethal means and methods of self-harm. | Goal 6 | The goal was revised to focus on reducing access to lethal means and methods among individuals with suicide risk.
5.1 | By 2005, increase the proportion of primary care clinicians, other health care providers, and health and safety officials who routinely assess the presence of lethal means (including firearms, drugs, and poisons) in the home and educate about actions to reduce associated risks. | 6.1 | The wording was revised: “Encourage providers who interact with individuals at risk for suicide to routinely assess for access to lethal means.”
5.2 | By 2005, expose a proportion of households to public information campaign(s) designed to reduce the accessibility of lethal means, including firearms, in the home. | 2.1 | Public information campaigns and other communications efforts, including those addressing lethal means, are discussed in Objective 2.1.
5.3 | By 2005, increase the proportion of the public that views consumers of mental health, substance abuse, and suicide prevention services as pursuing fundamental care and treatment for overall health. | 3.2 and 3.3 | This is now addressed in Objective 3.2, which focuses on reducing prejudice and discrimination associated with behavioral health disorders, and in Objective 3.3, which focuses on promoting the understanding that recovery is possible.
5.4 | By 2005, develop guidelines for safer dispensing of medications for individuals at heightened risk of suicide. | 7.3 | The objective is covered in Objective 7.3, which promotes the development and adoption of training guidelines for all health professions.
5.5 | By 2005, improve automobile design to impede carbon monoxide-mediated suicide. | 6.3 | The objective was broadened to address all types of safety technologies.
5.6 | By 2005, institute incentives for the discovery of new technologies to prevent suicide. | 6.3 | (see above)
Goal 6 | Implement training for recognition of at-risk behavior and delivery of effective treatment. | Goal 7 | The wording was revised: “Provide training to community and clinical service providers on the prevention of suicide and related behaviors.”
6.1 | By 2005, define minimum course objectives for providers of nursing care in assessment and management of suicide risk and identification and promotion of protective factors. Incorporate this material into curricula for nursing care providers at all professional levels. | 7.3 | The objective was broadened to address the education and training in all health professions and to include graduate and continuing education.
6.2 | By 2005, increase the proportion of physician assistant educational programs and medical residency programs that include training in the assessment and management of suicide risk and identification and promotion of protective factors. | 7.3 | (see above)
6.3 | By 2005, increase the proportion of clinical social work, counseling, and psychology graduate programs that include training in the assessment and management of suicide risk and the identification and promotion of protective factors. | 7.3 | (see above)
6.4 | By 2005, increase the proportion of clergy who have received training in identification of and response to suicide risk and behaviors and the differentiation of mental disorders and faith crises. | 7.1 | The new Objective 7.1 addresses the training of all community providers.
6.5 | By 2005, increase the proportion of educational faculty and staff who have received training on identifying and responding to children and adolescents at risk for suicide. | 7.1 | (see above)
6.6 | By 2005, increase the proportion of correctional workers who have received training on identifying and responding to persons at risk for suicide. | 7.1 | (see above)
6.7 | By 2005, increase the proportion of divorce and family law and criminal defense attorneys who have received training in identifying and responding to persons at risk for suicide. | 7.1 | (see above)
6.8 | By 2005, increase the proportion of counties (or comparable jurisdictions such as cities or tribes) in which education programs are available to family members and others in close relationships with those at risk for suicide. | 7.1 | (see above)
6.9 | By 2005, increase the number of recertification or licensing programs in relevant professions that require or promote competencies in depression assessment and management and suicide prevention. | 7.4 | The objective was revised to promote the adoption of core education and training guidelines on the prevention of suicidal self-directed violence and related behaviors by credentialing and accreditation bodies.
Goal 7 | Develop and promote effective clinical and professional practices. | Goal 8 | The goal was revised to promote suicide prevention as a core component of health care services.
7.1 | By 2005, increase the proportion of patients treated for self-destructive behavior in hospital emergency departments that pursue the proposed mental health follow-up plan. | 8.4 | The objective was revised to promote continuity of care and the safety and well-being of all patients treated for suicide risk in emergency departments or hospital inpatient units.
7.2 | By 2005, develop guidelines for assessment of suicidal risk among persons receiving care in primary health care settings, emergency departments, and specialty mental health and substance abuse treatment centers. | 9.1 | The objective was broadened to address the adoption of guidelines for the assessment of suicide risk among persons receiving care in all settings.
7.3 | By 2005, increase the proportion of specialty mental health and substance abuse treatment centers that have policies, procedures, and evaluation programs designed to assess suicide risk and intervene to reduce suicidal behaviors among their patients. | 9.5 | The wording was revised: “Adopt and implement policies and procedures to assess suicide risk and intervene to promote safety and reduce suicidal behaviors among patients receiving care for mental and/or substance use disorders.”
7.4 | By 2005, develop guidelines for aftercare treatment programs for individuals exhibiting suicidal behavior (including those discharged from inpatient facilities). Implement these guidelines in a proportion of these settings. | 9.2 | The objective was broadened to address guidelines for clinical practice and continuity of care for all providers who treat persons with suicide risk.
7.5 | By 2005, increase the proportion of those who provide key services to suicide survivors (e.g., emergency medical technicians, firefighters, law enforcement officers, funeral directors, clergy) who have received training that addresses their own exposure to suicide. | 10.5 | The objective was slightly revised: “Provide health care providers, first responders, and others with care and support when a patient under their care dies by suicide.”
7.6 | By 2005, increase the proportion of patients with mood disorders who complete a course of treatment or continue maintenance treatment as recommended. | 8.3 | Addressed in Objective 8.3, which focuses on promoting timely access to assessment, intervention, and effective care for individuals with a heightened risk for suicide.
7.7 | By 2005, increase the proportion of hospital emergency departments that routinely provide immediate post-trauma psychological support and mental health education for all victims of sexual assault and/or physical abuse. | 8.3 | (see above)
7.8 | By 2005, develop guidelines for providing education to family members and significant others of persons receiving care for the treatment of mental health and substance abuse disorders with risk of suicide. Implement the guidelines in facilities including general and mental hospitals, mental health clinics, and substance abuse treatment centers. | 9.4 | The wording was revised: “Adopt and implement guidelines to effectively engage families and concerned others, when appropriate, throughout entire episodes of care for persons with suicide risk.”
7.9 | By 2005, incorporate screening for depression, substance abuse, and suicide risk as a minimum standard of care for assessment in primary care settings, hospice, and skilled nursing facilities for all federally supported health care programs (e.g., Medicaid, CHAMPUS/TRICARE, CHIP, Medicare). | N/A | Screening for depression and alcohol misuse have now been endorsed by the United States Preventative Services Task Force (USPSTF) and are now covered as preventative services under Medicare. The PHQ-9 has been incorporated into the CMS Minimum Data Set for nursing home assessment.
7.10 | By 2005, include screening for depression, substance abuse, and suicide risk as measurable performance items in the Health Plan Employer Data and Information Set. | N/A | Screening for depression and alcohol misuse have now been endorsed by the USPSTF and are now covered as preventative services under Medicare.
Goal 8 | Improve access to and community linkages with mental health and substance abuse services. | 8.6, 8.7, and 8.8 | Objective 8.6 addresses linkages between behavioral health service providers and community-based programs. Objective 8.7 addresses coordination between behavioral health systems and local crisis centers. Objective 8.8 addresses collaborations between emergency departments and other health care providers.
8.1 | By 2005, increase the number of states that require health insurance plans to cover mental health and substance abuse services on par with coverage for physical health. | 5.4 and 1.5 | Parity laws are addressed in Objective 5.4, which supports efforts to increase access to and delivery of effective programs and services for mental and substance use disorders. Objective 1.5 promotes the integration of suicide prevention into all relevant health care reform efforts.
8.2 | By 2005, increase the proportion of counties (or comparable jurisdictions) with health and/or social services outreach programs for at-risk populations that incorporate mental health services and suicide prevention. | 8.3 | Covered in Objective 8.3, which promotes timely access to assessment, intervention, and effective care for individuals with a heightened risk for suicide.
8.3 | By 2005, define guidelines for mental health (including substance abuse) screening and referral of students in schools and colleges. Implement those guidelines in a proportion of school districts and colleges. | N/A | The revised objectives are broad and not focused on specific settings or populations.
8.4 | By 2005, develop guidelines for schools on appropriate linkages with mental health and substance abuse treatment services and implement those guidelines in a proportion of school districts. | N/A | (see above)
8.5 | By 2005, increase the proportion of school districts in which school-based clinics incorporate mental health and substance abuse assessment and management into their scope of activities. | N/A | (see above)
8.6 | By 2005, for adult and juvenile incarcerated populations, define national guidelines for mental health screening, assessment, and treatment of suicidal individuals. Implement the guidelines in correctional institutions, jails, and detention centers. | N/A | (see above)
8.7 | By 2005, define national guidelines for effective comprehensive support programs for suicide survivors. Increase the proportion of counties (or comparable jurisdictions) in which the guidelines are implemented. | 10.1 | The wording was revised: “Develop guidelines for effective comprehensive support programs for individuals bereaved by suicide and promote the full implementation of these guidelines at the state/territorial, tribal, and community levels.”
8.8 | By 2005, develop quality care/utilization management guidelines for effective response to suicidal risk or behavior and implement these guidelines in managed care and health insurance plans. | Goal 8, 8.5 | The incorporation of suicide prevention into continuous quality improvement efforts is an important theme in Goal 8 and is addressed in Objective 8.5.
Goal 9 | Improve reporting and portrayals of suicidal behavior, mental illness, and substance abuse in the entertainment and news media. | Goal 4 | Reworded to include online content: “Promote responsible media reporting of suicide, accurate portrayals of suicide and mental illnesses in the entertainment industry, and the safety of online content related to suicide.”
9.1 | By 2005, establish an association of public and private organizations for the purpose of promoting the accurate and responsible representation of suicidal behaviors, mental illness, and related issues on television and in movies. | 4.2 | Recommendations regarding accurate and responsible depictions have been developed. The objective was revised to encourage and recognize members of the entertainment media who follow the recommendations.
9.2 | By 2005, increase the proportion of television programs and movies that observe promoting accurate and responsible depiction of suicidal behavior, mental illness, and related issues. | 4.2 | (see above)
9.3 | By 2005, increase the proportion of news reports on suicide that observe consensus reporting recommendations. | 4.1 | Recommendations regarding reporting have been developed. The objective was revised to encourage their use.
9.4 | By 2005, increase the number of journalism schools that include in their curricula guidance on the portrayal and reporting of mental illness, suicide, and suicidal behaviors. | 4.4 | The objective was broadened to include mass communication schools.
Goal 10 | Promote and support research on suicide and suicide prevention. | Goal 12 | Promote and support research on suicide prevention.
10.1 | By 2002, develop a national suicide research agenda with input from survivors, practitioners, researchers, and advocates. | 12.1 and 12.2 | The Action Alliance’s Research Prioritization Task Force is developing a national research agenda. The new Objective 12.2 addresses the dissemination and use of the research agenda.
10.2 | By 2005, increase funding (public and private) for suicide prevention research, for research on translating scientific knowledge into practice, and for training of researchers in suicidology. | 13.1 and 13.2 | Objective 13.1 supports the evaluation of suicide prevention interventions. Objective 13.2 promotes the assessment, synthesis, and dissemination of the evidence obtained via these evaluations.
10.3 | By 2005, establish and maintain a registry of prevention activities with demonstrated effectiveness for suicide or suicidal behaviors. | 12.3 and 12.4 | A best practices registry has been established by the Suicide Prevention Resource Center. The new Objective 12.3 focuses on the timely dissemination of suicide prevention research findings. The new Objective 12.4 focuses on the development of a repository of research resources.
10.4 | By 2005, perform scientific evaluation studies of new or existing suicide prevention interventions. | 13.1 and 13.2 | Objective 13.1 supports the evaluation of suicide prevention interventions. Objective 13.2 promotes the assessment, synthesis, and dissemination of the evidence obtained via these evaluations.
Goal 11 | Improve and expand surveillance systems. | Goal 11 | The wording was revised: “Increase the timeliness and usefulness of national surveillance systems relevant to suicide prevention, and improve the ability to collect, analyze, and use this information for action.”
11.1 | By 2005, develop and refine standardized protocols for death scene investigations and implement these protocols in counties (or comparable jurisdictions). | 11.2 | Addressed in Objective 11.2, focuses on improving the usefulness and quality of suicide-related data.
11.2 | By 2005, increase the proportion of jurisdictions that regularly collect and provide information for follow-back studies on suicides. | 11.2 | (see above)
11.3 | By 2005, increase the proportion of hospitals (including emergency departments) that collect uniform and reliable data on suicidal behavior by coding external cause of injuries utilizing the categories included in the International Classification of Diseases. | 11.2 | (see above)
11.4 | By 2005, implement a National Violent Death Reporting System (NVDRS) that includes suicides and collects information not currently available from death certificates. | 11.3 | NVDRS, a state-based surveillance system that collects facts from different sources about the same incident, has been established by the Centers for Disease Control and Prevention, and currently operates in several states. The expansion of NVDRS is referenced in Objective 11.3.
11.5 | By 2005, increase the number of states that produce annual reports on suicide and suicide attempts, integrating data from multiple state data management systems. | 11.3 | The objective was broadened to promote the improvement and expansion of state/territorial, tribal, and local public health capacity to routinely collect, analyze, report, and use suicide-related data to implement prevention efforts and inform policy decisions.
11.6 | By 2005, increase the number of nationally representative surveys that include questions on suicidal behavior. | 11.4 | The objective was broadened to address other data collection instruments and systems, and to include questions on risk factors and exposure to suicide.
11.7 | By 2005, implement pilot projects in several states that link and analyze information related to self-destructive behavior derived from separate data systems, including law enforcement agencies, emergency medical services, and hospitals. | 11.3 | Addressed in Objective 11.3, which seeks to expand the capacity to collect, analyze, report, and use suicide-related data.

New objectives added in 2012:

■ Objective 1.2: Establish effective, sustainable, and collaborative suicide prevention programming at the state/territorial, tribal, and local levels.
■ Objective 2.2: Reach policymakers with dedicated communication efforts.
■ Objective 3.1: Promote effective programs and practices that increase protection from suicide risk.
■ Objective 5.3: Intervene to reduce suicidal thoughts and behaviors in populations with suicide risk.
■ Objective 7.2: Provide training to mental health and substance abuse providers on the recognition, assessment, and management of at-risk behavior and the delivery of effective clinical care for people with suicide risk.
■ Objective 8.1: Promote the adoption of “zero suicides” as an aspirational goal by health care and community support systems that provide services and support to defined patient populations.
■ Objective 8.2: Develop and implement protocols for delivering services for individuals with suicide risk in the most collaborative, responsive, and least restrictive settings.
■ Objective 8.5: Encourage health care delivery systems to incorporate suicide prevention and appropriate responses to suicide attempts as indicators of continuous quality improvement efforts.
■ Objective 9.3: Promote the safe disclosure of suicidal thoughts and behaviors by all patients.
■ Objective 9.6: Develop standardized protocols for use within emergency departments based on common clinical presentation to allow for more differentiated responses based on risk profiles and assessed clinical needs.
■ Objective 9.7: Develop guidelines on the documentation of assessment and treatment of suicide risk, and establish a training and technical assistance capacity to assist providers with implementation.
■ Objective 10.2: Provide appropriate clinical care to individuals affected by a suicide attempt or bereaved by suicide, including trauma treatment and care for complicated grief.
■ Objective 10.3: Engage suicide attempt survivors in suicide prevention planning, including support services, treatment, community suicide prevention education, and the development of guidelines and protocols for suicide attempt survivor support groups.
■ Objective 10.4: Adopt, disseminate, implement, and evaluate guidelines for communities to respond effectively to suicide clusters and contagion within their cultural context, and support implementation with education, training, and consultation.
■ Objective 12.2: Disseminate the national suicide prevention research agenda.
■ Objective 13.3: Examine how suicide prevention efforts are implemented in different states/territories, tribes, and communities to identify the types of delivery structures that may be most efficient and effective.
■ Objective 13.4: Evaluate the impact and effectiveness of the National Strategy for Suicide Prevention in reducing suicide morbidity and mortality.