# Acknowledgments

## National Action Alliance for Suicide Prevention Executive Committee (EXCOM)

The Honorable Secretary John M. McHugh

Secretary of the Army

Public Sector Co-Chair

The Honorable Senator Gordon H. Smith

President and CEO

National Association of Broadcasters

Private Sector Co-Chair

### Full Members

Talitha J. Arnold, MDiv

Senior Pastor

United Church of Santa Fe

Carl Bell, MD

President and CEO

Community Mental Health Council

Director

Institute for Juvenile Research

Department of Psychiatry

School of Medicine

University of Illinois at Chicago

Thomas J. Berger, PhD

Executive Director

Veterans Health Council for Vietnam

Veterans of America

Brian Boon, PhD

President and CEO

Commission on Accreditation of Rehabilitation

Robert Certain, DMin

Rector

The Episcopal Church of Saint Peter and Saint Paul

David Covington, LPC, MBA

Vice President

Adult and Youth Services

Maricopa County Regional

Behavioral Health Authority

Magellan Health Services

Judy Cushing

President and CEO

Oregon Partnership

Mary Durham, PhD

Vice President

The Center for Health Research

Kaiser Permanente

Brian Dyak

President and CEO

Entertainment Industries

Council, Inc.

Saul Feldman, PhD

Chairman Emeritus

United Behavioral Health

David Grossman, MD, MPH

Medical Director, Preventive Care

Group Health Research Institute

McClellan Hall, MA

Executive Director

National Indian Youth Leadership Project

Mary Hayashi, MBA

Eighteenth District

Chair, Assembly Business, Professions and Consumer Protection Committee

California State Assembly

Jack Heath

President and CEO

Inspire USA Foundation

Michael Hogan, PhD

Commissioner

New York State Office of Mental Health

Pamela Hyde, JD

Administrator

Substance Abuse and Mental Health Services Administration

U.S. Department of Health and Human Services

Robert Jesse, MD, PhD

Principal Deputy Under Secretary for Health

U.S. Department of Veterans Affairs

Andrew Lane

Executive Director

Johnson Family Foundation

Mary Lou Leary, JD

Acting Assistant Attorney General

Office of Justice Programs

U.S. Department of Justice

Beverly Malone, PhD, RN, FAAN

CEO

National League for Nursing

Walter A. McNeil, MS

Chief of Police

City of Quincy, Florida

Jamie Moyer

Co-founder

Moyer Foundation

Karen Moyer

Co-founder

Moyer Foundation

The Center for Health Research

Kaiser Permanente

Jerry Reed, PhD, MSW

Vice President and Director

Suicide Prevention Resource Center

Education Development Center, Inc.

Phil Satow, MA

Representative

National Council for Suicide Prevention

Paul M. Schyve, MD

Senior Advisor, Healthcare Improvement

The Joint Commission

David Theron Smith, MA

Divisional Vice President, Risk Management

Family Dollar Stores, Inc.

Joe Sullivan, JD

Chief Security Officer

Facebook, Inc.

Robert W. Turner

Senior Vice President, Corporate Relations

Union Pacific Railroad

Eduardo Vega, MA

Executive Director

Mental Health Association of San Francisco

Former Members

Derek Blumke

Co-founder and Former President

Student Veterans of America

Michael Botticelli, MEd

Director

Bureau of Substance Abuse Services

Massachusetts Department of Public Health

Helen Darling, MA

President and CEO

National Business Group on Health

Larry Echo Hawk, JD

Former Assistant Secretary of Indian Affairs

U.S. Department of the Interior

Kevin Jennings, MA, MBA

Former Assistant Deputy Secretary for Safe and Drug-Free Schools

U.S. Department of Education

Coloradas Mangas

Ruidoso High School

Mescalero, New Mexico

Gordon Mansfield, JD

Board Member

Wounded Warriors Project

Teri Popp, JD

Advocate

Laurie Robinson

Former Assistant Attorney General

Office of Justice Programs

U.S. Department of Justice

David Theron Smith, MA

Divisional Vice President, Risk Management

Family Dollar Stores, Inc.

### Ex-Officio Members

Regina Benjamin, MD, MBA

Surgeon General of the United States

Office of the Surgeon General

U.S. Department of Health and Human Services

Thomas Frieden, MD, MPH

Director

Centers for Disease Control and Prevention

U.S. Department of Health and Human Services

Kathy Greenlee, JD

Assistant Secretary for Aging

Administration on Aging

U.S. Department of Health and Human Services

Howard K. Koh, MD, MPH

Assistant Secretary for Health

U.S. Department of Health and Human Services

Thomas Insel, MD

Director

National Institute of Mental Health

National Institutes of Health

U.S. Department of Health and Human Services

Yvette Roubideaux, MD, MPH

Director

Indian Health Service

U.S. Department of Health and Human Services

Mary Wakefield, PhD, RN

Administrator

Health Resources and Services Administration

U.S. Department of Health and Human Services

## National Action Alliance for Suicide Prevention Task Forces

### American Indian/Alaska Native Task Force

McClellan Hall, MA (co-lead); Yvette Roubideaux, MD, MPH (co-lead); Larry Echo Hawk, JD (former co-lead); Patrick Anderson, JD; Patrese Atine; Erin Bailey; Dolores Subia Bigfoot, PhD; Sheila Cooper; Kathy Etz, PhD; Jodi Gillette, MPP; Megan Gregory; Teresa LaFromboise, PhD; Ron Lessard; Coloradas Mangas; Bill Martin; Debbie McBride; Cheryl Peterson, MN, RN; LaShawndra Price, PhD; Jeffrey Schulden, MD; Natasha Singh, JD; Michalyn Steele, JD; Rose Weahkee, PhD; Cortney Yarholar, LMSW; and Marilyn Zimmerman, MSW

### Clinical Care and Intervention Task Force

David Covington, LPC, MBA (co-lead); Mike Hogan, PhD (co-lead); Alan (Lanny) Berman, PhD, ABPP; Ed Coffey, MD; Kate Comtois, PhD, MPH; Chris Damle; Laurie Davidson, MA; John Draper, PhD; Shareh Ghani, MD; David Jobes, PhD; Christine Ketchmark, PsyD; Richard McKeon, PhD, MPH; Fred Meservey, LMSW; Gary O’Brien, DMin; Cindy Padilla; Phil Satow, MA; Paul Schyve, MD; Shannon Skowronski, MPH, MSW; and Heather Stokes, LCSW; and the following Magellan staff: Jose Abreu, PhD; Christian Comeau; Holly Dixon, MA, LAC; Gabriella Guerra, MSW; Meredith Mechenbier, LAC; Jill Robinson, LCSW; Roni Siebels, MSW; Liz Smithhart, LPC, CPRP, National Certified Counselor; and Gayle Tolman

### Clinical Workforce Preparedness Task Force

Brian Boon, PhD (co-lead); Elise S. Y. Young, LICSW, DCSW, (co-lead); Mariquita Mullan, PhD, MPH (former co-lead); Laurie Davidson, MA; Nina Heller, PhD; Alan Holmlund, MSW; Mitch Jewett, RN, CEN, CPEN; Cynthia Kane-Hyman, CNS; Linda Kaplan, MA; Bradley E. Karlin, PhD; Susan Keys, PhD; Deborah Klamen, MD, MHPE; John Lemich, MA; Richard Lieberman, MA; Lynn Linde, EdD; Brent Longtin, PMHCNS-BS; Erin Mahn; Anthony Pisani, PhD; Scott Poland, PhD; Verl Pope, EdD, LPC, NCC, CCMHC, ACS; Lori Rogers, MPA; David Rudd, PhD, ABPP; Heather Stokes, LCSW; and Brian Van Brunt, EdD, LPC

### Data and Surveillance Task Force

Robin Ikeda, MD, MPH (co-lead); Holly Hedegaard, MD, MSPH (co-lead); Jon Roesler, MS (former co-lead); Robert Bossarte, PhD; Alex Crosby, MD, MPH; Randy Hanzlick, MD; Regina Seider; Patricia Smith, MS; and Marjorie Warner, PhD

### Faith Communities Task Force

Talitha Arnold, MDiv (co-lead); Robert Certain, DMin (co-lead); Jean Beil, MA, MSW; Dolores Subia Bigfoot, PhD; Charles Fogelman, PhD; Kalman Kaplan, PhD; John Livingstone, EdD; Sherry Mollock, PhD; Pamela Ovwigho, PhD; Alice Perry, DMin; Wesley Smith, DMin; Elsie Weyrauch, RN; Jerry Weyrauch, MBA; and William Young, DMin, LMFT, LPC, CPT

### Lesbian, Gay, Bisexual, and Transgender (LGBT) Populations Suicide Task Force

Andrew Lane (co-lead); Mikel L. Walters, PhD (co-lead); David McFarland (former co-lead); Kevin Jennings, MA, MBA (former co-lead); Charles Robbins (former co-lead); Alan Acosta, MS; Amy Andre, MBA, MA; Kellan Baker, MPH, MA; Michael Botticelli, MEd; Thomas Bourdon; Eliza Byard, PhD; Michelle Carnes, PhD; Sylvia Fisher, PhD; Byron Garrett, MA; Ann Haas, PhD; David Kilmnick, PhD, MSW; Effie Malley, MPA; Nancy Martine-Alonzo; Henry Ng, MD; Kathleen O’Leary, MSW; Philip A. Rutter, PhD; Caitlin Ryan, PhD; Lance Toma, MA; and Garrett and Angela Wedel

### Military/Veterans Task Force

Jan Kemp, PhD, RN (co-lead); Maggie Haynes LaRocca, MA (co-lead); Donna Barnes, PhD; Alan (Lanny) Berman, PhD, ABPP; Derek Blumke; Sean Clark, JD; Judy Cushing; Jackie Garrick, LCSW-C, BCETS; Courtney Knowles; Chaplain (Colonel) William Sean Lee, DMin, BCC; Gordon Mansfield, JD; Robert Mays, Jr., PhD, MSW; Ken Norton, MSW, LICSW; Teri Popp, JD; A. Kathryn Power, MEd; Jonathan Pruden, MPS, Captain, USAF (Ret.); Kim Ruocco, MSW; and Eileen Zeller, MPH

### Public Awareness and Education Task Force

Jack Benson, MBA (co-lead); Brian Dyak (co-lead); Joe Sullivan, JD (co-lead); Mark Weber, MBA (co-lead); Monika Bickert, JD; Derek Blumke; Adam Conner; Anne Marie Cumming; Judy Cushing; Jeff Edwards; John Griffiths; Mary Hayashi, MBA; Jack Heath; Courtney Knowles; Gary Kreps, PhD, FAAHB; Alison Kreutzans; Richard Lieberman, MA; Wayne Lynch, MA; Karen Moyer; Teri Popp, JD; Dan Reidenberg, PsyD, FAPA; Mark Roth; Jason Rzepka; Nedra Weinreich, MS; Terry Wise, JD; and Fred Wolens

### Research Prioritization Task Force

Thomas Insel, MD (co-lead); Phillip Satow, MA (co-lead); Alan (Lanny) Berman, Ph.D, ABPP; Mary Durham, PhD; Saul Feldman, PhD; Thomas Friedan, MD, MPH; Robert Gebbia, MA; David Grossman, MD, MPH; Michael Hogan, PhD; Daniel Reidenberg, PsyD, FAPA; NIH support: Jane Pearson, PhD; Cynthia Claassen, PhD; Beverly Pringle, PhD; Joel Sherrill, PhD; Robert Heinssen, PhD, ABPP; Belinda Sims, PhD; Liza Bundesen, PhD; David Zielinski, PhD; Keisha Shropshire, MPH, CHES; Yancy Bodenstein, MS, MPH; Anne Sperling, PhD; Gemma Weiblinger, MA; Rex Robison, PhD; Janet Heekin, MLS; Sherry Davis Molock, PhD, MDiv; Chelsea Booth, PhD; Task Force Liaisons: Alex Crosby, MD, MPH (Data and Surveillance Task Force); Denise Juliano-Bult, MSW (Youth in Contact with the Justice System Task Force); Ira Katz, MD, PhD (National Strategy Revision/Update Task Force); Barbara Tatem Kelley, MA, MEd (Youth in Contact with the Justice System Task Force); Robert Mays, PhD (Military/Veterans Task Force); and Kathleen M. O’Leary, MSW (LGBT Populations Task Force)

### Suicide Attempt Survivors Task Force

John Draper, PhD (co-lead); Eduardo Vega, MA (co-lead); Chris Marshall (former co-lead); Heidi Bryan; Julie Cerel, PhD; Mark Davis, MA; Larry Fricks; Leah Harris, MA; DeQuincy Lezine, PhD; Edward Knight, PhD; Angela Mark; Lyn Morris, MFT; Shari Sinwelski, MS, EdS; and Stephanie Weber, MS

### Survivors of Suicide Loss Task Force

Joanne Harpel, JD, MPhil (co-lead); Karen Moyer (co-lead); Larry Berkowitz, EdD; Julie Cerel, PhD; Franklin Cook, MA; John (Jack) R. Jordan, PhD; Michelle Linn-Gust, PhD; Doreen S. Marshall, PhD; Vanessa McGann, PhD; John McIntosh, PhD; Robert Neimeyer, PhD; Ken Norton, LICSW; Naomi Powell; and Sally Spencer-Thomas, PhD

### Workplace Task Force

Beverly Malone, PhD, RN, FAAN, MA (co-lead); Helen Darling, MA (former co-lead); David Theron Smith, MA (former co-lead); Bob Anadell; Calvin Beyer, DBA, MPA; Connie DiCocco, MEd; Bernie Dyme AM, LCSW; Ron Finch, EdD; Ben Harrington, MA; Paul Heck, MEd; Jodi Jacobson, PhD; Patricia (Tricia) Kagerer, MA; Jungyai Ko, MSSA; Clare Miller; John Morrissey; Rich Paul, MSW; Alma Petrovic, MD, MPH; Adrienne Selko; Elizabeth Smith; Sally Spencer-Thomas, PsyD; and Bob VandePol, MSW

### Youth in Contact With the Juvenile Justice System Task Force

Joe Cocozza, PhD (co-lead); Melodee Hanes, JD (co-lead); Laurie Robinson (former co-lead); Donald Belau, PhD; Mari Kay Bickett, JD; Laurie Garduque, PhD; Robert Glover, PhD; Thomas Grisso, PhD; Lindsey Hayes, MS; Larke Huang, PhD; Denise Juliano-Bult, MSW; Ned Loughran; Shawn Marsh, PhD; Roy Praschil; Jeff Slowikowski, MPA; Deb Stone, ScD, MSW, MPH; Linda Teplin, PhD; Eric Truplin, PhD; Carl Wicklund; and David Devoursney, MPP. Task Force support staff include: Karen Stern, PhD; Kathleen Skowyra; Steffie Rapp, LCSW-C; Kara McDonagh, MSW, LGSW; Barbara Kelley, MA, Med; Simon Gonsoulin, Med; and Nick Read, MA

## Other Contributors

### Writers of Appendix D: Groups With Increased Suicide Risk

■ American Indians/Alaska Natives: Petrice Post, MA; Ellyson Stout, MS; and Cortney Yarholar, LMSW
■ Individuals Bereaved by Suicide: John (Jack) Jordan, PhD
■ Individuals in Justice and Child Welfare Settings: Lindsay Hayes, MS; Jason H. Padgett, MPA, MSM; and Katherine Wootten Deal, MPH
■ Individuals Who Engage in Non-Suicidal Self-Injury: Morton Silverman, MD
■ Individuals Who Have Attempted Suicide: Eduardo Vega, MA
■ Individuals with Medical Conditions: Morton Silverman, MD
■ Individuals with Mental and Substance Use Disorders: Morton Silverman, MD; and Michael Botticelli, MEd
■ Lesbian, Gay, Bisexual, and Transgender (LGBT) Populations: Ann Haas, PhD; Andrew Lane; and Effie Malley, MPA
■ Members of the Armed Forces and Veterans: Leonard Litton, III, Colonel (Ret.); Ira Katz, MD, PhD; and Jan Kemp, RN, PhD
■ Men in Midlife: John R. Blosnich, PhD, MPH; and Eric Caine, MD
■ Older Men: Yeates Conwell, MD; and Alisa O’Riley, PhD

### Community-Based Workshop Participants

Robert Anderson, PhD; Catherine Barber, MPA; Don Belau, PhD; Carl Bell, MD; Robert Bossarte, PhD; Ryan Breshears, PhD; Heidi Bryan; Eric Caine, MD; Donna Carender, MS; Yeates Conwell, MD; Lisa Colpe, PhD; Katherine Wootten Deal, MPH; Mark Evans, PhD; Barri Faucett, MA; Amy Fiske, PhD, CBSM; Ann Haas, PhD; Katherine Hempstead, PhD; Jeff Inman, MS; Sean Joe, PhD; Ira Katz, MD, PhD; Jan Kemp, PhD, RN; Marilyn Koenig; Lesley Levin, LCSW; Gary McConahay, PhD; Richard McKeon, PhD; Doreen S. Marshall, PhD, LPC; Elaine de Mello, LCSW; Matthew Miller, MD, MPH, ScD; Jason H. Padgett, MPA, MSM; Rich Paul, MSW; Richard Ramsay, MSW, RSW; Jerry Reed, PhD, MSW; Dan Reidenberg, PsyD, FAPA; Scott Ridgway, MS; Karl Rosston, LCSW; Jeremiah Simmons; Pat Smith, MS; and Hyong Un, MD

### Listening Session Contributors

- Garrett Lee Smith Memorial Act/SAMHSA Campus Grantee Meeting (January 26, 2011)
- Garrett Lee Smith Memorial Act/SAMHSA State/Tribal Grantee Meeting (February 17, 2011)
- Behavioral Health Subcommittee at the Legislative and Policy Conference of the National Association of County Behavioral Health and Developmental Disability Directors, held in association with the spring meeting of the National Association of Counties (March 5, 2011)
- Department of Defense, Department of Veterans Affairs Suicide Prevention Conference (March 16, 2011)
- Annual Conference of the American Association of Suicidology (April 14, 2011)
- National Council for Community Behavioral Healthcare Conference (May 2, 2011)

### Other Reviewers

Ella Arensman, PhD, MSc; Deborah, Azrael, PhD; Cathy Barber, MPA; David W. Fleming, MD; David Grossman, MD, MPH; Jeff Levi, PhD; Lars Mehlum MD, PhD; Matthew Miller, ScD; Paul Quinnett, PhD

### Staff Support

Maryland Arciaga; Emily Barocas; Colleen Carr, MPH; Renata Casiel; Katherine Wootten Deal, MPH; Ingrid Donato; Magdala Labre, PhD, MPH; Liz Lebreton, MPH; David Litts, OD; Liliya Melnyk; Chris Miara, MS; Jason H. Padgett, MPA, MSM; Laurie Rosenblum, MPH; and Xan Young, MPH

We also would like to acknowledge the important contributions of the numerous individuals who provided input and public comments throughout the revision process.