# References

1 Goldstick J. E., Cunningham R. M., & Carter P. M. (2022). Current Causes of Death in Children and Adolescents in the United States. The New England Journal of Medicine, 386(20), 1955–1956. 10.1056/NEJMc2201761 35443104
2 Centers for Disease Control and Prevention, National Center for Health Statistics. (2023). National Center for Health Statistics Mortality data on CDC WONDER [Database]. U.S. Department of Health and Human Services. https://wonder.cdc.gov/Deaths-by-Underlying-Cause.html
3 Schumacher S., Kirzinger A., Presiado M., Valdes I., & Brodie M. (2023). Americans’ experiences with gun-related violence, injuries and deaths. KFF. https://www.kff.org/other/poll-finding/americans-experiences-with-gun-related-violence-injuries-and-deaths/
4 Centers for Disease Control and Prevention. (2024, April). Firearm homicide trends. U.S. Department of Health and Human Services. https://www.cdc.gov/firearm-violence/php/data-trends/firearm-homicide-trends.html
5 Centers for Disease Control and Prevention. (2024, April). Firearm suicide trends. U.S. Department of Health and Human Services. https://www.cdc.gov/firearm-violence/php/data-trends/firearm-suicide-data-trends.html
6 Grinshteyn E., & Hemenway D. (2019). Violent death rates in the US compared to those of the other high-income countries, 2015. Preventive Medicine, 123, 20–26. 10.1016/j.ypmed.2019.02.026
7 McGough M., Amin K., Panchal N., & Cox C. (2023). Child and teen firearm mortality in the U.S. and peer countries. KFF. https://www.kff.org/mental-health/issue-brief/child-and-teen-firearm-mortality-in-the-u-s-and-peer-countries/
8 Office of Mental Health and Suicide Prevention. (2023). 2023 National veteran suicide prevention annual report. U.S. Department of Veterans Affairs. https://www.mentalhealth.va.gov/docs/data-sheets/2023/2023-National-Veteran-Suicide-Prevention-Annual-Report-FINAL-508.pdf
9 Zeoli A. M., Malinski R., & Turchan B. (2016). Risks and targeted interventions: Firearms in intimate partner violence. Epidemiologic Reviews, 38(1), 125–139. 10.1093/epirev/mxv007 26739680
10 Federal Bureau of Investigation. (2015). Uniform crime reporting program data: supplementary homicide reports, 2013. U.S. Department of Justice. 10.3886/ICPSR36124.v1
11 Smith E. L. (2022). Female murder victims and victim-offender relationship, 2021. U.S. Department of Justice, Bureau of Justice Statistics. https://bjs.ojp.gov/female-murder-victims-and-victim-offender-relationship-2021
12 Panchal N. (2024). The impact of gun violence on children and adolescents. KFF. https://www.kff.org/mental-health/issue-brief/the-impact-of-gun-violence-on-children-and-adolescents/
13 Gun Violence Archive (n.d.). Mass shootings in 2022. Retrieved May 15, 2024. https://www.gunviolencearchive.org/reports/mass-shooting?year=2022
14 Gun Violence Archive (n.d.). Past summary ledgers. Retrieved May 15, 2024. https://www.gunviolencearchive.org/past-tolls
15 Gun Violence Archive. (n.d.). GVA- 10 year review. Retrieved March 15, 2024. https://www.gunviolencearchive.org/
16 Fowler K. A., Leavitt R. A., Betz C. J., Yuan K., & Dahlberg L. L. (2021). Examining differences between mass, multiple, and single-victim homicides to inform prevention: Findings from the National Violent Death Reporting System. Injury Epidemiology, 8(1), 49. 10.1186/s40621-021-00345-7 34365969
17 Geller L. B., Booty M., & Crifasi C. K. (2021). The role of domestic violence in fatal mass shootings in the United States, 2014-2019. Injury Epidemiology, 8(1), 38. 10.1186/s40621-021-00330-0 34053458
18 American Psychological Association. (2019, August 15). One, third of US adults say fear of mass shootings prevents them from going to certain places or events. https://www.apa.org/news/press/releases/2019/08/fear-mass-shooting
19 Silver J., Simons A., & Craun S. (2018). A study of the pre-attack behaviors of active shooters in the United States between 2000–2013. Federal Bureau of Investigation, U.S. Department of Justice. https://www.fbi.gov/file-repository/pre-attack-behaviors-of-active-shooters-in-us-2000-2013.pdf/view
20 Metzl J. M., & MacLeish K. T. (2015). Mental illness, mass shootings, and the politics of American firearms. American Journal of Public Health, 105(2), 240–249. 10.2105/AJPH.2014.302242 25496006
21 Kane R. A., Lopez B. E., & Haskins P. A. (2023). National Institute of Justice special report: Public mass shootings research. National Institute of Justice, U.S. Department of Justice. https://www.ojp.gov/pdffiles1/nij/307401.pdf
22 Swanson J. W., McGinty E. E., Fazel S., & Mays V. M. (2015). Mental illness and reduction of gun violence and suicide: Bringing epidemiologic research to policy. Annals of Epidemiology, 25(5), 366–376. 10.1016/j.annepidem.2014.03.004 24861430
23 Substance Abuse and Mental Health Services Administration. (2023, April 24). Mental health myths and facts. U.S. Department of Health and Human Services. https://www.samhsa.gov/mental-health/myths-and-facts#:~:text=Myth%3A%20People%20with%20mental%20health,with%20a%20serious%20mental%20illness
24 Teplin L. A., McClelland G. M., Abram K. M., & Weiner D. A. (2005). Crime victimization in adults with severe mental illness: Comparison with the National Crime Victimization Survey. Archives of General Psychiatry, 62(8), 911–921. 10.1001/archpsyc.62.8.911 16061769
25 American Psychological Association. (2013). Gun violence: Prediction, prevention, and policy. https://www.apa.org/pubs/reports/gun-violence-prevention
26 National Threat Assessment Center. (2023). Mass attacks in public spaces: 2016–2020. U.S. Secret Service, Department of Homeland Security. https://www.secretservice.gov/sites/default/files/reports/2023-01/usss-ntac-maps-2016-2020.pdf
27 Kaufman E. J., Wiebe D. J., Xiong R. A., Morrison C. N., Seamon M. J., & Delgado M. K. (2021). Epidemiologic trends in fatal and nonfatal firearm injuries in the US, 2009-2017. JAMA Internal Medicine, 181(2), 237–244. 10.1001/jamainternmed.2020.6696 33284327
28 Fowler K. A., Dahlberg L. L., Haileyesus T., & Annest J. L. (2015). Firearm injuries in the United States. Preventive Medicine, 79, 5–14. 10.1016/j.ypmed.2015.06.002 26116133
29 Rivara F. P., Hink A. B., Kuhls D. A., Banks S., Agoubi L. L., Kirkendoll S., Winchester A., Hoeft C., Patel B., & Nathens A. (2023). Firearm injuries treated at trauma centers in the United States. Journal of Trauma and Acute Care Surgery, 96(6), 955–964. 10.1097/ta.0000000000004172 37872675
30 Zwald M. L., Van Dyke M. E., Chen M. S., Radhakrishnan L., Holland K. M., Simon T. R., Dahlberg L. L., Friar N. W., Sheppard M., Kite-Powell A., & Mercy J. M. (2023). Emergency department visits for firearm injuries before and during the COVID-19 pandemic — United States, January 2019-December 2022. Morbidity and Mortality Weekly Report, Centers for Disease Control and Prevention, 72(13), 333–337. 10.15585/mmwr.mm7213a2
31 Herrera-Escobar J. P., de Jager E., McCarty J. C., Lipsitz S., Haider A. H., Salim A., & Nehra D. (2021). Patient-reported outcomes at 6 to 12 Months among survivors of firearm injury in the United States. Annals of Surgery, 274(6), e1247–e1251. 10.1097/SLA.0000000000003797 32530586
32 Vella M. A., Warshauer A., & Tortorello G., Fernandez-Moure J., Giacolone J., Chen B., Cabulong A., Chreiman K., Sims C., Schwab C. W., Reilly P. M., Lane-Fall M., & Seamon M. J. (2020). Long-term functional, psychological, emotional, and social outcomes in survivors of firearm injuries. JAMA Surgery, 155(1), 51–59. 10.1001/jamasurg.2019.4533 31746949
33 Orlas C. P., Thomas A., Herrera-Escobar J. P., Price M. A., Haider A. H., & Bulger E. M. (2021). Long-term outcomes of firearm injury survivors in the United States: The National Trauma Research Action Plan scoping review. Annals of Surgery, 274(6), 962–970. 10.1097/SLA.0000000000005204 34784664
34 Ranney M., Karb R., Ehrlich P., Bromwich K., Cunningham R., & Beidas R. S. (2019). What are the long-term consequences of youth exposure to firearm injury, and how do we prevent them? A scoping review. Journal of Behavioral Medicine, 42(4), 724–740. 10.1007/s10865-019-00035-2 31367937
35 Song Z., Zubizarreta J. R., Giuriato M., Koh K. A., & Sacks C. A. (2023). Firearm injuries in children and adolescents: Health and economic consequences among survivors and family members. Health Affairs, 42(11). 10.1377/hlthaff.2023.00587
36 Song Z., Zubizarreta J. R., Giuriato M., Paulos E., & Koh K. A. (2022). Changes in health care spending, use, and clinical outcomes after nonfatal firearm injuries among survivors and family members a cohort study. Annals of Internal Medicine, 175(6), 795–803. 10.7326/M21-2812 35377713
37 Vasan A., Mitchell H. K., Fein J. A., Buckler D. G., Wiebe D. J., & South E. C. (2021). Association of neighborhood gun violence with mental health-related pediatric emergency department utilization. JAMA Pediatrics, 175(12), 1244–1251. 10.1001/jamapediatrics.2021.3512 34542562
38 Houry D. E., Simon T. R., & Crosby A. E. (2022). Firearm homicide and suicide during the COVID-19 pandemic: Implications for clinicians and health care systems. JAMA, 327(19), 1867–1868. 10.1001/jama.2022.6924 35536830
39 Hureau D. M., Wilson T., Rivera-Cuadrado W., & Papachristos A. V. (2022). The experience of secondary traumatic stress among community violence interventionists in Chicago. Preventive Medicine, 165(Part A), 107186. 10.1016/j.ypmed.2022.107186 35940475
40 Lowe S. R., & Galea S. (2017). The mental health consequences of mass shootings. Trauma, Violence, & Abuse, 18(1), 62–82. 10.1177/1524838015591572
41 Gavulic K. A., & Gonzales G. (2021). Did the Orlando shooting at Pulse Nightclub affect sexual minority mental health? Results and challenges using population-based data. Journal of Gay & Lesbian Mental Health, 25(3), 252–264. 10.1080/19359705.2020.1819501
42 Southern Poverty Law Center, Everytown for Gun Safety Support Fund, & Polarization and Extremism Research and Innovation Lab. (2023). U.S. youth attitudes on guns report. https://www.splcenter.org/peril-youth-attitudes-guns-report
43 Deb P., & Gangaram A. (2021). Effects of school shootings on risky, behavior, health and human capital. National Bureau of Economic Research. 10.3386/w28634
44 Rossin-Slater M., Schnell M., Schwandt H., Trejo S., & Uniat L. (2020). Local exposure to school shootings and youth antidepressant use. Proceedings of the National Academy of Sciences of the United States of America, 117(38), 23484–23489. 10.1073/pnas.2000804117 32900924
45 Levine P. B., & McKnight R. (2020). Exposure to a school shooting and subsequent well-being [Working paper]. National Bureau of Economic Research. 10.3386/w28307
46 Hodges J. C., Walker D. T., Baum C. F., & Hawkins S. S. (2023). Impact of school shootings on adolescent school safety, 2009-2019. American Journal of Public Health, 113(4), 438–441. 10.2105/AJPH.2022.307206 36758203
47 Brener N. D., Simon T. R., Anderson M., Barrios L. C., & Small M. L. (2002). Effect of the incident at Columbine on students’ violence- and suicide-related behaviors. American Journal of Preventive Medicine, 22(3), 146–150. 10.1016/s0749-3797(01)00433-0 11897457
48 Comer B. P., & Connolly E. J. (2023). Exposure to gun violence and handgun carrying from adolescence to adulthood. Social Science & Medicine, 328, 115984. 10.1016/j.socscimed.2023.115984 37245260
49 Bancalari P., Sommer M. & Rajan S. (2022). Youth exposure to endemic community gun violence: A systematic review. Adolescent Research Review, 7, 383–417. 10.1007/s40894-022-00178-5
50 Healthy People 2030. (n.d.). Crime and Violence. U.S. Department of Health and Human Services, Office of Disease Prevention and Health Promotion. Retrieved March 15, 2024. https://health.gov/healthypeople/priority-areas/social-determinants-health/literature-summaries/crime-and-violence
51 Kravitz-Wirtz N., Bruns A., Aubel A. J., Zhang X., & Buggs S. A. (2022). Inequities in community exposure to deadly gun violence by race/ethnicity, poverty, and neighborhood disadvantage among youth in large US cities. Journal of Urban Health: Bulletin of the New York Academy of Medicine, 99, 610–625. 10.1007/s11524-022-00656-0 35672546
52 Leibbrand C., Rivara F., & Rowhani-Rahbar A. (2021). Gun violence exposure and experiences of depression among mothers. Prevention Science: The Official Journal of the Society for Prevention Research, 22, 523–533. 10.1007/s11121-020-01202-7 33439439
53 Schlüter B. S., Alburez-Gutierrez D., Bibbins-Domingo K., Alexander M. J., & Kiang M. V. (2024). Youth experiencing parental death due to drug poisoning and firearm violence in the US, 1999-2020. JAMA. 10.1001/jama.2024.8391
54 Merrick M. T., Ford D. C., Ports K. A., Guinn A. S., Chen J., Klevens J., Metzler M., Jones C. M., Simon T. R., Daniel V. M., Ottley P., & Mercy J. A. (2019). Vital Signs: Estimated proportion of adult health problems attributable to adverse childhood experiences and implications for prevention - 25 states, 2015-2017 Morbidity and Mortality Weekly Report, Centers for Disease Control and Prevention, 68(44), 999–1005. 10.15585/mmwr.mm6844e1
55 Wintemute G. J. (2015). The epidemiology of firearm violence in the twenty-first century United States. Annual Review of Public Health, 36, 5–19. 10.1146/annurev-publhealth-031914-122535
56 Hink A. B., Bonne S., Levy M., Kuhls D. A., Allee L., Burke P. A., Sakran J. V., Bulger E. M., & Stewart R. M. (2019). Firearm injur research and epidemiology: A review of the data, their limitations, and how trauma centers can improve firearm injury research. The Journal of Trauma and Acute Care Surgery, 87(3), 678–689. 10.1097/TA.0000000000002330 31033891
57 Price J. H., & Khubchandani J. (2017). Adolescent homicides, suicides, and the role of firearms: A narrative review. American Journal of Health Education, 48(2), 67–79. 10.1080/19325037.2016.1272507
58 Miller M. & Hemenway D. (1999). The relationship between firearms and suicide: A review of the literature. Aggression and Violent Behavior, 4(1), 59–75. 10.1016/S1359-1789(97)00057-8
59 Shah G. H., Shankar P., Schwind J. S., & Sittaramane V. (2020). The detrimental impact of the Covid-19 crisis on health equity and social determinants of health. Journal of Public Health Management and Practice, 26(4), 317–319. 10.1097/PHH.0000000000001200 32433385
60 Abrams E. M., Greenhawt M., Shaker M., Pinto A. D., Sinha I., & Singer A. (2022). The COVID-19 pandemic: Adverse effects on the social determinants of health in children and families. Annals o Allergy, Asthma & Immunology: Official publication of the American College of Allergy, Asthma, & Immunology, 128(1), 19–25. 10.1016/j.anai.2021.10.022
61 Green H., Fernandez R., & MacPhail C. (2021). The social determinants of health and health outcomes among adults during the COVID-19 pandemic: A systematic review. Public Health Nursing 38(6), 942–952. 10.1111/phn.12959 34403525
62 Miller M., Zhang W., & Azrael D. (2022). Firearm purchasing during the COVID-19 pandemic: Results from the 2021 National Firearms Survey. Annals of Internal Medicine, 175(2), 219–225. 10.7326/M21-3423 34928699
63 Aspen Health Strategy Group. (2024). Reducing the health harms of firearm injury. The Aspen Institute. https://www.aspeninstitute.org/publications/reducing-the-health-harms-of-firearm-injury/
64 Kim D. (2019). Social determinants of health in relation to firearm-related homicides in the United States: A nationwide multilevel cross-sectional study. PLOS Medicine, 16(12), e1002978. 10.1371/journal.pmed.1002978 31846474
65 Chapman B.P., Peters K., Kannan V., Hutchison M., Lapham S., Caine E. D., & Conner K. R. (2022). Intergenerational social mobility and suicide risk by firearm and other means in US males. Journal of Psychiatric Research, 156, 318–323. 10.1016/j.jpsychires.2022.10.037 36306710
66 Niamatullah S., Auchincloss A., Finkel R., & Gibson A. (2023). Gun deaths in big cities. Drexel University, Urban Health Collaborative. https://drexel.edu/uhc/resources/briefs/BCHC%20Gun%20Deaths/
67 Reeping P. M., Mak A., Branas C. C., Gobaud A. N., & Nance M. L. (2023). Firearm death rates in rural vs urban U.S. counties. JAMA Surgery, 158(7), 771–772. 10.1001/jamasurg.2023.0265 37099312
68 Bailey Z. D., Krieger N., Agénor M., Graves J., Linos N., & Bassett M. T. (2017). Structural racism and health inequities in the USA: Evidence and interventions. Lancet, 389(10077), 1453–1463. 10.1016/S0140-6736(17)30569-X 28402827
69 Houghton A., Jackson-Weaver O., Toraih E., Burley N., Byrne T., McGrew P., Duchesne J., Tatum D., & Taghavi S. (2021). Firearm homicide mortality is influenced by structural racism in US metropolitan areas. Journal of Trauma and Acute Care Surgery, 91(1), 64–71. 10.1097/TA.0000000000003167 33797488
70 Braveman P. A., Arkin E., Proctor D., Kauh T., & Holm N. (2022). Systemic and structural racism: Definitions, examples, health damages, and approaches to dismantling. Health Affairs, 41(2), 171–178. 10.1377/hlthaff.2021.01394 35130057
71 Kegler S.R., Simon T.R., Zwald M.L., Chen M. S., Mercy J. A., Jones C. M., Mercado-Crespo M. C., Blair J. M., Stone D. M., Ottley P. G., & Dills J. (2022). Vital Signs: Changes in firearm homicide and suicide rates — United States, 2019-2020. Morbidity and Mortality Weekly Report, Centers for Disease Control and Prevention, 71(19), 656–663. 10.15585/mmwr.mm7119e1
72 Anglemyer A., Horvath T., & Rutherford G. (2014). The accessibility of firearms and risk for suicide and homicide victimization among household members. Annals of Internal Medicine, 160(2), 101–110. 10.7326/M13-1301 24592495
73 Grossman D. C., Mueller B. A., & Riedy C. (2005). Gun f storage practices and risk of youth suicide and unintentional firearm injuries. JAMA, 293(6), 707–714. 10.1001/jama.293.6.707 15701912
74 Braga A. A., Griffiths E., Sheppard K., & Douglas S. (2021). Firearm instrumentality: Do guns make violent situations more lethal?. Annual Review of Criminology, 4, 147–164. 10.1146/annurev-criminol-061020-021528
75 Cai Z., Junus A., Chang Q., & Yip P. S. F. (2022). The lethality of suicide methods: A systematic review and meta-analysis. Journal of Affective Disorders, 300, 121–129. 10.1016/j.jad.2021.12.054 34953923
76 Paashaus L., Forkmann T., Glaesmer H., Juckel G., Rath D., Schönfelder A., & Teismann T. (2021). From decision to action: Suicidal history and time between decision to die and actual suicide attempt. Clinical Psychology & Psychotherapy, 28(6), 1427–1434. 10.1002/cpp.2580 33687121
77 Simon T. R., Swann A. C., Powell K. E., Potter L. B., Kresnow M. J., & O’Carroll P. W. (2001). Characteristics of impulsive suicide attempts and attempters. Suicide and Life-Threatening Behavior, 32(Supplement to Issue 1), 49–59. 10.1521/suli.32.1.5.49.24212 11924695
78 Centers for Disease Control and Prevention. (2024, April). Facts about Suicide. U.S. Department of Health and Human Services. https://www.cdc.gov/suicide/facts/index.html
79 Fowler K. A., Kaplan M. S., Stone D. M., Zhou H., Stevens M. R., & Simon T. R. (2022). Suicide among males across the lifespan: An analysis of differences by known mental health status. American Journal of Preventive Medicine, 63(3), 419–422. 10.1016/j.amepre.2022.02.021 35987559
80 Stone D. M., Simon T. R., Fowler K. A., Kegler S. R., Yuan K., Holland K. M., Ivey-Stephenson A. Z., & Crosby A. E. (2018). Vital signs: Trends in state suicide rates - United States, 1999-2016 and circumstances contributing to suicide - 27 states, 2015. Morbidity and Mortality Weekly Report, Centers for Disease Control and Prevention, 67(22), 617–624. 10.15585/mmwr.mm6722a1
81 Betz M. E., Stanley I. H., Buck-Atkinson J., Johnson R., Bryan C. J., Baker J. C., Bryan A. O., Hunter K., & Anestis M. D. (2023). Firearm owners’ preferences for locking devices: Results of a national survey. Annals of Internal Medicine, 176(3), 424–427. 10.7326/M22-3113 36745884
82 Miller M., & Azrael D. (2022). Firearm storage in US households with children: Findings from the 2021 National Firearm Survey. JAMA, 5(2), e2148823. 10.1001/jamanetworkopen.2021.48823
83 Wilson R. F., Mintz S., Blair J. M., Betz C. J., Collier A., & Fowler K. A. (2023). Unintentional firearm injury deaths among children and adolescents aged 0–17 years — National Violent Death Reporting System, United States, 2003–2021. Morbidity and Mortality Weekly Report, Centers for Disease Control and Prevention, 72, 1338–1345. 10.15585/mmwr.mm7250a1
84 Centers for Disease Control and Prevention. (2024, April). About the public health approach to violence prevention. U.S. Department of Health and Human Services. https://www.cdc.gov/violence-prevention/about/about-the-public-health-approach-to-violence-prevention.html
85 National Cancer Institute. (2024, March). Adult tobacco use. U.S. Department of Health and Human Services, National Institutes of Health. https://progressreport.cancer.gov/prevention/adult_smoking
86 Centers for Disease Control and Prevention (2023, May). Current cigarette smoking among adults in the United States. U.S. Department of Health and Human Services. https://www.cdc.gov/tobacco/data_statistics/fact_sheets/adult_data/cig_smoking/index.htm
87 National Safety Council. (2024). Historical fatality trends: Car crash deaths and rates. https://injuryfacts.nsc.org/motor-vehicle/historical-fatality-trends/deaths-and-rates/#:~:text=In%202021%2C%20the%20death%20rate,per%20100%20million%20miles%20drive
88 Institute of Medicine and National Research Council. (2013). Priorities for research to reduce the threat of firearm-related violence. https://nap.nationalacademies.org/catalog/18319/priorities-for-research-to-reduce-the-threat-of-firearm-related-violence
89 Stark D. E &, Shah N. H. (2017). Funding and publication of research on gun violence and other leading causes of death. JAMA, 317(1), 84–85. 10.1001/jama.2016.16215 28030692
90 Cunningham R. M., Ranney M. L., Goldstick J. E., Kamat S. V., Roche J. S., & Carter P. M. (2019). Federal funding for research on the leading causes of death among children and adolescents. Health Affairs, 38(10), 1653–1661. 10.1377/hlthaff.2019.00476 31589521
91 Office of Justice Programs. (2024). Community violence intervention. U.S. Department of Justice. https://www.ojp.gov/topics/community-violence-intervention
92 Center for Gun Violence Solutions. (n.d.). Community Violence Intervention. Johns Hopkins Bloomberg School of Public Health. Retrieved March 15, 2024. https://publichealth.jhu.edu/center-for-gun-violence-solutions/solutions/community-violence-intervention
93 Purtle J., Dicker R., Cooper C., Corbin T., Greene M. B., Marks A., Creaser D., Topp D., & Moreland D. (2013). Hospital-based violence intervention programs save lives and money. Journal of Trauma and Acute Care Surgery, 75(2), 331–333. 10.1097/TA.0b013e318294f518 23887566
94 Health Alliance for Violence Intervention. (n.d.). What is a hospital-based violence intervention program (HVIP)?. Retrieved March 15, 2024. https://www.thehavi.org/what-is-an-hvip
95 Occupational Safety and Health Administration. (2017). Enforcement procedures and scheduling for occupational exposure to workplace violence. U.S. Department of Labor. https://www.osha.gov/enforcement/directives/cpl-02-01-058
96 Dowd M. D., Sege R. D., Gardner H. G., Quinlan K. P., Ewald M. B., Ebel B. E., Lichenstein R., Melzer-Lange M. D., O’Neil J., Pomerantz W. J., Powell E. C., Scholer S. J., & Smith G. A. (2012). Firearm-related injuries affecting the pediatric population. Pediatrics, 130(5), e1416–e1423. 10.1542/peds.2012-2481 23080412
97 McLean R. M., Harris P., Cullen J., Maier R. V., Yasuda K. E., Schwartz B. J., & Benjamin G. C. (2019). Firearm-related injury and death in the United States: A call to action from the nation’s leading physician and public health professional organizations. Annals of Internal Medicine, 171(8), 573–577. 10.7326/M19-2441 31390463
98 Buggs S. A. L., Kravitz-Wirtz N. D., & Lund J. J. (2022). Social and structural determinants of community firearm violence and community trauma. ANNALS of the American Academy of Political and Social Science, 704(1), 224–241. 10.1177/00027162231173324
99 Center for Gun Violence Solutions. (n.d.). Safe and Secure Gun Storage. Johns Hopkins Bloomberg School of Public Health. Accessed May 23, 2024. https://publichealth.jhu.edu/center-for-gun-violence-solutions/solutions/safe-and-secure-gun-storage
100 Center for Gun Violence Solutions. (n.d.). Firearm Purchaser Licensing. Johns Hopkins Bloomberg School of Public Health. Accessed May 23, 2024. https://publichealth.jhu.edu/center-for-gun-violence-solutions/solutions/firearm-purchaser-licensing
101 Gun Control Act, 18 USC § 922 (d), (g). (2024). https://uscode.house.gov/view.xhtml?req=(title:18%20section:922%20edition:prelim)
102 Center for Gun Violence Solutions. (n.d.). Extreme Risk Protection Orders (ERPOs). Johns Hopkins Bloomberg School of Public Health. Accessed May 23, 2024. https://publichealth.jhu.edu/center-for-gun-violence-solutions/solutions/extreme-risk-protection-orders-or-red-flag-laws
103 Webster D. (2021). Policies that reduce gun violence: Restricting large capacity magazines. Johns Hopkins Bloomberg School of Public Health. https://publichealth.jhu.edu/2021/policies-that-reduce-gun-violence-restricting-large-capacity-magazines
104 Koper C.S. (2020). Assessing the potential to reduce deaths and injuries from mass shootings through restrictions on assault weapons and other high-capacity semiautomatic firearms. Criminology & Public Policy, 19(1), 147–170. 10.1111/1745-9133.12485
105 Greene M. (2013). Review of gun safety technologies. U.S. Department of Justice, National Institute of Justice. https://nij.ojp.gov/library/publications/review-gun-safety-technologies
106 Timmer-Murillo S. C., Schroeder M. E., Trevino C., Geier T. J., Schramm A. T., Brandolino A. M., Hargarten S., Holena D., de Moya M., Milia D., & deRoon-Cassini T. A. (2023). Comprehensive framework of firearm violence survivor care: A review. JAMA Surgery, 158(5), 541–547. 10.1001/jamasurg.2022.8149 36947025
107 National Academies of Sciences, Engineering, and Medicine. (2019). Health systems interventions to prevent firearm injuries and death. 10.17226/25354
108 U.S. Department of Health and Human Services. (2024). 2024 National strategy for suicide prevention. https://www.hhs.gov/programs/prevention-and-wellness/mental-health-substance-abuse/national-strategy-suicide-prevention/index.html
109 Youth.gov. (n.d.). School based mental health. Interagency Working Group on Youth Programs. Accessed March 15, 2024. https://youth.gov/youth-topics/youth-mental-health/school-based
110 The White House. (2022). Biden-Harris Administration announces two new actions to address youth mental health crisis [Fact sheet]. https://www.whitehouse.gov/briefing-room/statements-releases/2022/07/29/fact-sheet-biden-harris-administration-announces-two-new-actions-to-address-youth-mental-health-crisis/