# Introduction

## Firearm violence^a^ in America is a public health crisis.

Since 2020, firearm-related injury has been the leading cause of death for U.S. children and adolescents (ages 1–19), surpassing motor vehicle crashes, cancer, and drug overdose and poisoning (Figure 1).^1, 2^

In 2022, 48,204 total people died from firearm-related injuries, including suicides, homicides, and unintentional deaths.^2^ This is over 8,000 more lives lost than in 2019 and over 16,000 more lives lost than in 2010.^2^

FIGURE 1 Firearms are the leading cause of death for children and adolescents

Firearms are the leading cause of death for children and adolescents

A recent nationally representative survey (n=1,271) found that the majority of U.S. adults or their family members (54%) have experienced a firearm-related incident.^3^ Among all respondents, 21% have personally been threatened with a firearm, 19% have a family member who was killed by a firearm (including by suicide), 17% have witnessed someone being shot, 4% have shot a firearm in self-defense, and 4% have been injured by a firearm (Figure 2).^3^ Nearly 6 in 10 U.S. adults say that they worry “sometimes,” “almost every day,” or “every day,” about a loved one being a victim of firearm violence.^3^ Such high levels of exposure to firearm violence for both children and adults give rise to a cycle of trauma and fear within our communities, contributing to the nation’s mental health crisis.

This Advisory describes the public health crisis of firearm violence in America and describes strategies for firearm injury and violence prevention, with a focus on the health and well-being of children, families, and communities.

FIGURE 2 Firearm violence is pervasive in the United States

Based on a recent nationally representative survey, 54% of U.S. adults report that either they, or a family member have experienced a firearm-related incident.

a In this Advisory, “firearm violence” includes firearm-related homicide, suicide, nonfatal firearm injuries, and unintentional injuries and deaths.