# About This Advisory

A Surgeon General’s Advisory is a public statement that calls the American people’s attention to an urgent public health issue. Advisories are reserved for significant public health challenges that require the nation’s immediate awareness and action.

This document is not an exhaustive review of the literature. Rather, the advisory was developed through a substantial review of the available scientific evidence, primarily found via electronic searches of research articles published in English and resources suggested by subject matter experts, with priority given to meta-analyses and systematic literature reviews. The morbidity and mortality data discussed account only for officially reported and documented incidents of firearm violence. Researchers have long acknowledged that reported firearm-related incidents represent an underestimate of the number of actual firearm-related incidents that occur.