# Other Resources

This is a non-exhaustive list that can be helpful to learn more about firearm-related violence prevention. If you or someone you know is struggling or in crisis, help is always available. Call or text [underlined: 988] or chat 988lifeline.org

- Addressing Trauma and Mass Violence, SAMHSA (https://www.samhsa.gov/blog/addressing-trauma-mass-violence), provides resources for those experiencing grief following mass shootings. It also offers resources developed by the National Child Traumatic Stress Network.
- Gun Violence, National Institute of Justice (https://nij.ojp.gov/topics/crime/violent-crime/gun-violence), houses a library of publications, events and trainings, articles, and funding opportunities for understanding and addressing firearm violence.
- National Strategy for Suicide Prevention, U.S. Department of Health and Human Services (https://www.hhs.gov/programs/prevention-and-wellness/mental-health-substance-abuse/national-strategy-suicide-prevention/index.html), provides concrete recommendations for a coordinated and comprehensive approach to addressing gaps in the suicide prevention field.
- Preventing Firearm Injury and Death, CDC (https://www.cdc.gov/firearm-violence/prevention/index.html), overviews strategies to reduce firearm injuries and death.
- Prevention Resource Finder, U.S. Department of Homeland Security (https://www.dhs.gov/prevention), provides information on the resources needed to help prepare for and prevent targeted violence and terrorism.
- Reducing Gun Violence, U.S. Department of Justice (https://www.justice.gov/doj/reducing-gun-violence), includes fact sheets on safe firearm storage, information on efforts to reduce violent crime, and other resources.
- Resource for School Administrators on Importance of Safe Firearm Storage, U.S. Department of Education (https://www.ed.gov/news/press-releases/us-department-education-issues-new-resource-school-administrators-importance-safe-firearm-storage), provides tools that schools can use to communicate with parents and families about the importance of safe firearm storage.
- Suicide Prevention is Everyone’s Business: A Toolkit for Safe Firearm Storage, U.S. Department of Veterans Affairs (https://www.mentalhealth.va.gov/suicide_prevention/docs/Toolkit_Safe_Firearm_Storage_CLEARED_508_2-24-20.pdf), guides communities through the process of building coalitions to raise awareness about safe storage.
- Suicide Prevention Resource for Action, CDC (https://www.cdc.gov/suicide/resources/prevention.html), describes the best available evidence for suicide prevention.
- Trauma and Violence, SAMHSA (https://www.samhsa.gov/trauma-violence), provides additional information and resources for understanding and addressing trauma and its impacts.
- Violence Prevention Resources for Action, CDC (https://www.cdc.gov/violence-prevention/php/resources-for-action/index.html), provides information to help communities make decisions based on the best available evidence to prevent different forms of violence.
- Violence Research Initiatives, NIH (https://obssr.od.nih.gov/about/violence-research-initiatives), supports scientific research and provides information to increase understanding on firearm injury and mortality prevention.