# Additional Recent Resources on Prevention Strategies

This is not a comprehensive list:

- American Academy of Pediatrics American Academy of Pediatrics, Technical Report 2022: Firearm-Related Injuries and Deaths in Children and Youth (https://doi.org/10.1542/peds.2022-060071). The AAP leads a nonpartisan national coalition of medical, public health, and research organizations dedicated to firearm violence prevention research. This report provides evidence for specific interventions to reduce firearm violence in the U.S., with a specific focus on children and adolescents. This report also includes a review of the effectiveness of legislation in firearm injury prevention.
- Aspen Health Strategy Group Reducing the Health Harms of Firearm Injury (https://www.aspeninstitute.org/publications/reducing-the-health-harms-of-firearm-injury/), 2024. The mission of the Aspen Health Strategy Group, part of the Health, Medicine & Society Program at the Aspen Institute, is to promote improvements in policy and practice by providing leadership on complex health issues. This compilation document explores the causes and consequences of firearm violence and opportunities—using the tools of public health—to lessen the toll of injury and death associated with firearms.
- Johns Hopkins Center for Gun Violence Solutions U.S. Gun Violence in 2021: An Accounting of a Public Health Crisis (https://publichealth.jhu.edu/sites/default/files/2024-01/2023-june-cgvs-u-s-gun-violence-in-2021-v3.pdf). The Center for Gun Violence Solutions develops and applies scientific research to identify a range of firearm violence solutions and advocates for systemic changes. This report discusses a public health approach to prevent firearm violence using a population level approach that addresses both firearm access and the factors that contribute to and protect from firearm violence.
- RAND The Science of Gun Policy: A Critical Synthesis of Research Evidence on the Effects of Gun Policies in the United States (https://www.rand.org/pubs/research_reports/RRA243-4.html), Third Edition 2023. The RAND Corporation launched the Gun Policy in America initiative to create resources where policymakers and the public can access information on effective firearm policies. This report, now in its third edition, synthesizes the available scientific evidence for the effects of various firearm policies.