# Conclusion

This Advisory describes the health impact of firearm violence in the U.S. The increasing number of children and adolescents dying from firearm-related injuries and the reverberating mental health impacts on society make firearm violence an urgent public health crisis in America.

There are many experts and leaders who work tirelessly each day to protect families and communities from the trauma and suffering that have become all too common in our country. They include community leaders, health workers, and educators and school staff who emphasize healing and connection and lead violence-intervention initiatives in their neighborhoods. They also include researchers, medical associations, and community-based organizations whose actionable recommendations to mitigate firearm violence are advancing efforts to save lives.

But it will take more—the collective commitment of the nation—to turn the tide on the crisis of firearm violence in America. A public health approach can guide our strategy and actions, as it has done in the past with successful efforts to address tobacco-related disease and motor vehicle crashes. It is up to us to take on this generational challenge with the urgency and clarity the moment demands. The safety and well-being of our children and future generations are at stake.