# Chapter 4 Public Health Approach to Firearm Injury and Violence Prevention

A public health approach is designed to prevent and reduce harm by changing the conditions and circumstances that contribute to risk of firearm violence as measured by deaths, injuries, as well as the reverberating mental health and emotional impacts detailed in this Advisory.

This cross-sector approach complements the work of clinical health care providers to treat those who are victims and survivors of violence and the work of law enforcement to hold perpetrators accountable. To be successful, this approach must include everyone, from firearm owners to health workers to community leaders.

The CDC has defined a public health approach to violence prevention, which can be used to address a range of public health crises, as a four-step process rooted in a systematic and scientific method.^84^ First, the problem must be defined and monitored. Second, risk and protective factors must be identified. Third, prevention strategies must be developed and tested to determine their effectiveness in preventing injuries, and fourth, widespread adoption must be assured through implementation and dissemination strategies based on available evidence. Widespread adoption relies on and is supported by strong collaborations between state/federal leaders and community organizations/local leadership.

During an emergency, like that of firearm violence in the U.S., a public health approach requires combining the best available scientific evidence with scientific judgment and expertise to take life-saving action quickly. This involves simultaneously implementing promising prevention strategies and policies, continuing to gather more evidence, and iterating to improve interventions. This entire approach is continuous and iterative.

Past successful public health approaches have focused on prevention and addressed population level risk, taking a solution-oriented and evidence-informed approach. For example, this approach contributed to a more than 70% decline in the prevalence of cigarette smoking among U.S. adults, from 42% in 1964 to 11.5% in 2021.^85, 86^ In another example, the enactment and enforcement of traffic safety laws, reinforced by public health education campaigns, led to sustained and improved motor vehicle safety. According to the National Safety Council, the mileage death rate in 1923 (21.65 deaths per 100 million miles driven) has decreased by more than 93% in 2021 (1.38 deaths per 100 million miles driven).^87^ The public health approaches to cigarette smoking and motor vehicle crashes achieved success through changes to policies, systems, and environments such as evidence-informed laws (e.g. age-minimums for tobacco purchases, driver’s licenses), evidence-driven changes in products themselves (e.g. air bags, seat belts), and evidence-driven public health education campaigns. Taking such an approach to firearm violence prevention has the potential to curb the alarming trends of firearm-related injury and death in America and the resulting health impacts.

The remainder of this section describes critical components of a public health approach to firearm violence prevention, building on the earlier sections of the Advisory which define the problem and identify risk and protective factors. It describes the need for critical research investments to accelerate the public health approach, provides an overview of prevention strategies, and discusses ways to address the mental health toll of firearm violence.

Taking a public health approach to firearm violence prevention has the potential to curb the alarming trends of firearm-related injury and death in America and the resulting health impacts.

## Critical Research Investments

Firearm violence prevention is dependent on a strong foundation of research.

Researchers, community leaders, government officials, and health workers widely acknowledge the critical need to increase research funding for the improvement of data collection and analysis to inform and evaluate firearm violence prevention strategies. Historical underfunding for firearm violence prevention research has created challenges for expanding the evidence-base and implementing life-saving policies.^88^ The federal investment in firearm violence research is drastically less than the federal investment in research for causes of death with comparable mortality.^89^ For example, in relation to mortality rates over a 10-year period (2004–2014), firearm violence killed about as many people as sepsis but funding for firearm violence research was less than 1% of that for sepsis.^89^ Over the same period, research for firearm violence was funded at a similar level to research on drowning; yet the firearm-related mortality rate (age-adjusted) was nearly 7 times as high: 10.25 per 100,000 (350,139 firearm-related fatalities) compared to 1.47 per 100,000 (49,891 drowning-related fatalities).^2, 89^ Among children and adolescents (ages 1–18), federal research dollars between 2008–2017 totaled $878 million for motor vehicle crashes, averaging $26,136 per youth death.^90^ In contrast, during the same period, firearm injury prevention federal research dollars totaled $12 million, averaging $597 per youth death.^90^ A significant increase of funding for firearm injury and mortality research is necessary to expand our understanding of the causes of and the strategies to reduce and prevent firearm violence in America.

These critical research investments include:

- Improve data sources and data collection to inform prevention activities. Accurate, timely, publicly accessible, detailed, and nationally comprehensive firearm injury data systems are needed. For example, there is no national data collection system that includes all nonfatal firearm injuries and, thus, many states and communities are unable to access or utilize data on nonfatal firearm injuries. Without proper data, the extent and severity of firearm violence outcomes as well as evaluations of prevention efforts and interventions will be limited. Prioritizing coordination across organizations that have access to firearm injury data (health systems, states, localities, public health agencies, non-profits, law enforcement, etc.) will allow for more complete analysis of firearm violence.
- Expand research to examine short-term and long-term outcomes of firearm violence and evaluate specific prevention strategies. Multiple research gaps related to firearm-related violence and injury prevention have been described, including but not limited to, community-based firearm violence, suicide prevention, shootings by law enforcement, mass shootings, domestic violence involving firearms, reducing risks to children and adolescents, the use of firearm-related technology, and the effects of existing policies and laws. Research should also evaluate health outcomes of individuals directly and indirectly exposed to firearm violence, including survivors, their families, and communities. Additionally, research should be expanded to evaluate the effectiveness of firearm violence prevention strategies in new settings or within sub-populations, and to support follow-up evaluations of the long-term outcomes associated with such strategies.
- Conduct implementation science research to improve effectiveness of prevention strategies. There are existing firearm violence prevention strategies that have evidence of effectiveness. However, expanding support and investment for implementation science research is necessary to improve the uptake of evidence-based strategies, policies, and practices in communities. Implementation science research can support the adoption, implementation, and sustainment of evidence-based prevention strategies and also help ensure that such strategies are not having any unintended impact.

## Community Risk Reduction and Education Prevention Strategies

While increased funding and growing the evidence base are vital to informing effective firearm violence prevention strategies, we can take action now to reduce firearm-related injuries and deaths.

Prevention strategies should include investments in community-based interventions and educational programs that have the potential to prevent firearm-related death and injury.

- Implement community violence interventions to support populations with increased risk of firearm violence involvement. Community violence interventions (CVI) use evidence-informed, multidisciplinary, and tailored strategies to disrupt cycles of violence and connect individuals at risk of violence involvement with services that address trauma and improve physical, social, and economic circumstances.^91^ The CVI approach employs credible messengers and practitioners to resolve potential violent conflicts and deliver key intervention elements such as connecting individuals with healthcare, housing, employment services, and other resources.^92^ Similarly, hospital-community partnerships can connect those who have experienced violence, or are at risk for violence, with appropriate services. Hospita-based violence intervention programs (HVIPs) typically combine a short intervention in the hospital with intense case management and services in the community upon release^.93, 94^
- Incorporate organizational violence prevention and emergency preparedness elements into safety programs. These programs may include systematic models for early intervention such as the establishment of behavioral threat assessment and management (BTAM) teams^l^, as well as emergency action plans to address the threat from firearm violence. Communities can facilitate the development of traum-informed preparedness and response plans for schools and the implementation of student programs before, during, and after school to ensure safety. Organizations can implement workplace violence prevention programs and take steps to mitigate workplace violence through appropriate changes to the physical environment, administrative processes, and employee training^.95^
- Encourage health systems to facilitate education on safe and secure firearm storage. Health systems can support health workers in talking with patients during routine and preventive medical visits about safe storage of firearms, as well as the temporary transfer of a firearm during a high-risk period. Unlocked firearms pose a safety risk and can be accessed by unauthorized users, including family members with dementia or suicidal thoughts, children and adolescents, or through theft. The American Medical Association, American Academy of Family Physicians, American Academy of Pediatrics, American Public Health Association, American College of Physicians, American College of Surgeons, and American Psychiatric Association all support counseling of patients on firearm injury prevention, among additional prevention strategies.^96, 97^
- Address structural determinants that increase the risk of firearm violence. All communities in the U.S. are affected by firearm violence, but higher rates of community firearm violence are concentrated in historically marginalized communities.^98^ To decrease risk of firearm violence exposure, injury, and/or death, communities can, for example, promote and invest in safe and supportive physical environments and housing, equitable access to high-quality education and health care, and opportunities for employment and economic growth.

## Firearm Risk Reduction Prevention Strategies

In addition to community-based prevention strategies, public health leaders and policymakers can use available scientific evidence combined with scientific judgment and expertise to consider prevention strategies that build distance in terms of time and space between firearms and people who are at risk of harming themselves or others.

- Require safe and secure firearm storage, including child access prevention laws. Safe and secure firearm storage means that firearms are stored unloaded and locked in a secure place, such as a firearm safe that is only accessible to authorized users, and that ammunition is stored separately from the firearm(s).^99^ Various safe storage and child access prevention laws have been implemented at the state level to require safe storage of firearms and penalize those who put children at risk due to failures related to safe storage.
- Implement universal background checks and expand purchaser licensing laws. Universal background checks would expand on current federal law (which requires any person engaged in the business^m^ of dealing firearms to obtain a license and conduct background checks) to include mandatory background checks for all firearm purchases, including private sales and transferring/gifting firearms. Firearm purchaser licensing, or permit-to-purchase laws, vary by jurisdiction but may be further augmented by enhancing minimum age requirements for all firearm purchases and requiring additional steps to physically possess a firearm, such as safety training requirements and/or a built-in waiting period between the purchase and the possession of a firearm.^100^
- Implement effective firearm removal policies. Extreme Risk Protection Orders (ERPOs)^n^ and Domestic Violence Protection Orders (DVPOs) are complementary civil court orders, each with defined due process protections and that share the common goal of preventing harm. DVPO and ERPO laws vary by jurisdiction and operate in different contexts. DVPOs, which have been implemented in some capacity in all 50 states^o^, primarily focus on protecting victims of domestic violence. Federal law bans the purchase or possession of firearms by individuals convicted of a felony and/or misdemeanor crime of domestic violence and most people subject to a final DVPO^p^.^101^ ERPOs, which have been implemented in fewer states, are mechanisms that can temporarily prohibit individuals at risk of harming themselves or others from purchasing or possessing a firearm, and in such circumstances, they can also allow for the temporary removal of firearms already in a person’s possession.^102^
- Ban assault weapons and large-capacity magazines for civilian use. Assault weapons may encompass automatic weapons^q^ and some semiautomatic weapons that may include military-style features that make the firearm more lethal, such as detachable large-capacity magazines. A large-capacity magazine (also known as a high-capacity magazine) is commonly defined as a device that has the capacity to hold more than 10 rounds of ammunition.^103^ Mass shootings that involve a firearm with a large-capacity magazine result in significantly more injuries and deaths than shootings that do not involve such magazines.^104^
- Create safer conditions in public places related to firearm use and carry, including through policies that govern who can carry a loaded firearm in public spaces, concealed or open, and through rules around using deadly force with a firearm in public situations where the individual(s) could have safely retreated without firing a weapon.
- Treat firearms like other consumer products. Unlike motor vehicles which have safety standards that are regulated by the National Highway Traffic Safety Administration (NHTSA), pesticides that are regulated by the Environmental Protection Agency (EPA), or prescription drugs that are regulated by the Food and Drug Administration (FDA), there are no federal standards or regulations regarding the safety of firearms produced in the U.S. Therefore, firearms manufactured and sold in the U.S. may not undergo safety testing or include safety features like warning labels related to associated risk or authorized-use technology (“smart” firearm technology) for firearm access.^105^ Treating firearms as a consumer product^r^ could result in changes which may enhance safety.

## Mental Health Access and Support

The mental health burden and trauma for those exposed to firearm violence warrants greater attention and action through increased mental health supports and trauma-informed resources.

- Prioritize increased access to affordable, high-quality mental health care, substance use treatment, and other trauma-informed resources. Health workers and community-based organizations can address the mental health consequences associated with firearm violence by providing a continuum of trauma-informed care for individuals who experience firearm violence, especially disproportionately impacted youth, families, and communities.^106, 107^ Health systems and health workers can connect individuals at risk for suicide to timely mental health resources and care.^108^ Policymakers can provide support to sustain mental health access and crisis support services.
- Enhance safety measures and mental health resources in learning settings for children and adolescents. This can include the expansion of a school-based mental health workforce to build a positive school climate and the capacity and resources needed to connect students to mental health services.^109^ Most recently, the Bipartisan Safer Communities Act provided historic levels of funding to address youth mental health, including $2 billion for the U.S. Department of Education to create safe, inclusive learning environments for students and to hire and train more mental health professionals for schools—where students are most likely to receive these crucial services.^110^

l BTAM offers a systematic and fact-based model for early intervention in potential cases of violence. BTAM teams are multidisciplinary groups comprised of providers from education, mental health, social services, law enforcement, faith community, and other community support stakeholders who assess threats and develop case management strategies, creating a non-punitive alternative to criminal justice interventions for individuals at risk of mobilizing to violence. (U.S. Department of Homeland Security. (n.d.) Threat assessment and management teams. Office for Targeted Violence and Terrorism Prevention. https://www.dhs.gov/sites/default/files/publications/threat_assessment_and_management_team_v7.pdf)

m A Federal rule was recently amended to broaden the definition of when a person is considered “engaged in the business” as a dealer in firearms and makes clear that any person engaged in the business of dealing firearms must get licensed and conduct background checks for all firearm sales. (U.S. Department of Justice. (2024). Definition of “engaged in the business” as a dealer in firearms. https://www.federalregister.gov/documents/2024/04/19/2024-07838/definition-of-engaged-inthe-business-as-a-dealer-in-firearms)

n ERPOs may be referred to by other names, such as “red flag laws,” depending on the state.

o The specific laws, procedures, and terminology regarding DVPOs may vary from state to state.

p In 2022, the implementation of the Bipartisan Safer Communities Act narrowed the so-called “boyfriend loophole” by prohibiting dating partners convicted of domestic violence from purchasing or possessing firearms. (Congressional Research Service. (2022). Firearms eligibility: Domestic violence and dating partners. https://crsreports.congress.gov/product/pdf/IF/IF12210)

q Civilian ownership of fully automatic firearms is heavily restricted or banned in most jurisdictions. In 1986, the Firearm Owners Protection Act banned the possession or transfer of machine guns (a common subset of automatic weapons) that were not registered before 1986, effectively prohibiting the manufacture of new machine guns for civilian ownership after that date. (Firearm Owners’ Protection Act, P.L. 99–308 (1986). https://www.govinfo.gov/content/pkg/PLAW-109publ92/html/PLAW-109publ92.htm).

r Currently, the Protection of Lawful Commerce in Arms Act (PLCAA), which was signed into law in 2005, provides that manufacturers, distributors, dealers, and importers of firearms or ammunition products, in the U.S. cannot be held liable when crimes are committed with their products. (Protection of Lawful Commerce in Arms Act, P.L. 109–93 (2005). https://uscode.house.gov/view.xhtml?path=/prelim@title15/chapter105&edition=prelim).