# Chapter 3 Contributing Factors to Firearm Violence

The factors strongly associated with firearm-related deaths and injuries in the U.S. are complex.^55, 56, 57, 58^

The COVID-19 pandemic impacted several known contributing factors to firearm violence with a disproportionate impact on marginalized communities.^59, 60, 61^ Furthermore, leading up to and during the COVID-19 pandemic, an estimated 5.4 million U.S. adults in a household without a firearm purchased a firearm for the first time.^62^

Developing an understanding of the social determinants of health^j^, impacts of firearm violence exposure, and other factors that contribute to firearm violence in the U.S. is critical to addressing this public health crisis. While not an exhaustive list, the following section discusses important factors that may contribute to rates of firearm violence in the U.S.

## Socioeconomic, Geographic, and Racial Inequities

Socioeconomic, geographic, and racial inequities as well as the associations between these factors may contribute to firearm violence outcomes and exposure. Structural factors that significantly increase the risk of experiencing firearm violence include, “poverty, living in an area with low social mobility, or being in a historically marginalized group impacted by structural racism,” among others.^63^

A nationwide study found that social capital (levels of trust in institutions), social mobility, income inequality, and social service spending demonstrated significant associations with firearm homicide rates.^64^ Specifically, a one standard deviation increase in upward social mobility was related to a 25% reduction in the firearm homicide rate, and increased institutional social capital was linked to a 17% decrease in the number of firearm homicide incidents.^64^ Similarly, an increase in socioeconomic status by one standard deviation has been associated with a 31% reduction in firearm suicide risk among men.^65^ Conversely, increases in the neighborhood percentages of residents living in poverty and of males living alone were associated with up to 27% and 12% higher firearm-related homicide rates, respectively.^64^

Regarding geographic factors, firearm homicide rates are generally higher in urban areas (metropolitan counties) and firearm suicide rates are often higher in rural areas (non-metropolitan counties). Data analyzed from the Big Cities Health Coalition reported a total of 67,000 firearm deaths (2010–2021) in 35 member cities, 66% of which were homicides and 32% were suicides.^66^ Further, in a cross-sectional study from 2011 to 2020, the most rural counties had a 76% higher firearm-related suicide rate and a 46% lower firearm-related homicide rate compared to the most urban counties.^67^

Structural, institutional, and individual racism have also contributed to inequities in exposure to firearm violence in the U.S. For example, structural racism has contributed to inequities in economic, housing, and educational opportunities that are associated with risk for violence and other health conditions among racial and ethnic minority groups.^68, 69^ Racial and ethnic minority population groups are more likely to live in neighborhoods with concentrated economic disadvantage due to imposed economic setbacks, historic divestment, and harmful discriminatory policies like redlining.^70^ In 2020, counties with the highest levels of poverty experienced firearm homicide rates 4.5 times as high, and firearm suicide rates 1.3 times as high, as counties with the lowest poverty levels.^71^

## Lethality, Availability, and Access

In 2022, the majority of all homicides (79% [19,651 of 24,849]) and suicides (55% [27,032 of 49,476]) in the U.S. were carried out with a firearm.^2^ When discussing the contributing factors to the firearm violence crisis in the U.S., the lethality, availability of, and access to firearms should be acknowledged. The presence of a firearm in the home has been associated with higher risk of being a victim of homicide and suicide among all household members, and an unlocked firearm in the home is associated with higher risk of suicide and unintentional firearm injury among children and adolescents.^72, 73^

Studies suggest that a fatal outcome is more likely when a firearm is used in a violent situation or in a suicide attempt rather than other methods.^28, 74^ Nearly 90% of suicide attempts with a firearm end in death, a case fatality rate (CFR) that exceeds that of hanging/suffocation (CFR: 84.5%), drowning (CFR: 80.4%), gas poisoning (CFR: 56.6%), jumping (CFR: 46.7%), drug/liquid poisoning (CFR: 8.0%), and cutting (CFR: 4.0%).^75^ Acts of violence and suicide attempts often involve a rapid transition from thought to action, and access to a firearm during a time of acute stress can lead to deadly outcomes. Some suicide attempt survivors report that they acted within minutes or hours of deciding to end their lives.^76, 77^

Suicide is one of the top leading causes of death in the United States for individuals ages 10–64.^78^ While mental health is an important risk factor for suicide, many people who die by suicide (all means) do not have a known mental health condition.^79, 80^ As such, people who die by suicide may not come to the attention of health workers when effective prevention interventions could be delivered. Research shows that negative life events, such as family relationship problems, job-related stress, physical health issues, and financial or legal problems, are common circumstances of suicide, including among those without a mental health diagnosis.^80^ While the relationship between mental illness and suicide risk is complex, it is clear that access to a firearm can turn a moment of crisis into a fatal one. Attempting suicide by firearm is almost always an irreversible act that allows for little or no reconsideration by an individual.

While the relationship between mental illness and suicide risk is complex, it is clear that access to a firearm can turn a moment of crisis into a fatal one.

Firearm storage practices^k^ vary widely among firearm owners. A 2022 survey found that among firearm owners, most of whom owned more than one firearm (65%), 71% used one type of storage or locking device on at least one firearm, but 65% reported at least one unlocked firearm.^81^ Even among firearm owners with children, findings from a national survey (n=1363) in 2021 suggest that 36% have unlocked firearms.82 Unlocked firearms can be accessed by unauthorized users, including family members with dementia or suicidal thoughts, children and adolescents, or through theft. According to a 2023 CDC analysis, 56% of unintentional firearm deaths among children and adolescents (ages 0–17) happened while they were in their own home, and approximately two-thirds (67%) of shooters were playing with or showing the firearm to others when it discharged.^83^ The firearms used in these unintentional deaths were often stored loaded (74%) and unlocked (76%) and were most commonly accessed from sleeping areas such as nightstands, under a mattress or pillow, or on a bed (Figure 6).^83^

FIGURE 6 Analysis of unintentional firearm deaths among children and adolescents

Analysis of unintentional firearm deaths among children and adolescents

j The U.S. Department of Health and Human Services (HHS) defines social determinants of health as, “the conditions in the environments where people are born, live, learn, work, play, worship, and age that affect a wide range of health, functioning, and quality-of-life outcomes and risks.” (Office of Disease Prevention and Health Promotion. (n.d.) Social determinants of health. Department of Health and Human Services, Office for the Assistant Secretary of Health. Retrieved March 15, 2024. https://health.gov/healthypeople/priority-areas/social-determinants-health)

k Safe storage and secure storage are complementary. Safe means unloaded, and secure means locked up. (Center for Gun Violence Solutions. (n.d.) Safe and secure gun storage. Johns Hopkins Bloomberg School of Public Health. Retrieved March 15, 2024. https://publichealth.jhu.edu/center-for-gun-violence-solutions/solutions/safe-and-secure-gun-storage).