# Chapter 2 The Collective Toll of Firearm Violence Exposure in the U.S.

Beyond the profound consequences of surviving a firearm-related injury, those who do not experience direct bodily harm often grapple with mental health consequences related to firearm violence exposure^i^, including community members, children and adolescents, and families.

## Impact on Communities

There is increasing evidence that exposure to firearm violence can contribute to elevated stress levels and mental health challenges and threaten the sense of well-being for entire communities. One study examining emergency department admissions between 2014 and 2018 found that children and adolescents in west and southwest Philadelphia, who lived within two to three blocks of where a shooting occurred, had nearly 50% increased odds of using an emergency room for mental health reasons during the subsequent 30 days after the shooting than other children and adolescents.^37^ The odds were highest among youth who were exposed to multiple shootings and among those who lived closest to a shooting’s location.^37^

Health workers who regularly treat firearm-related injuries and are exposed to the consequences of firearm violence may experience secondary traumatic stress.^38^ The same can be seen among community workers and law enforcement officers who directly interface with victims and survivors of firearm violence. For example, in a study population of Chicago community violence interventionists (trained civilians working to intervene in and de-escalate street and firearm violence), 94% of workers reported at least one secondary traumatic stress indicator in the prior seven days (e.g., feeling emotionally numb, having trouble concentrating or sleeping, reliving the trauma experienced by clients).^39^

Mass shootings, in particular, can contribute to widespread psychological distress, as these events often implicate whole communities, receive substantial media coverage, and embed themselves in the public consciousness.^40^ Among U.S. adults, 79% report experiencing stress from the possibility of a mass shooting and 33% say fear prevents them from going to certain places or events.^18^ For example, the Orlando shooting at Pulse nightclub in June 2016, a shooting that impacted the LGBTQ+ community, was associated with a 25.6 percentage point increase in severe psychological distress for sexual minority men nationwide compared to heterosexual men.^41^

## Impact on Children and Adolescents

Fears and worries about firearm violence are highly prevalent among youth, especially regarding school shootings. A nationally representative survey found that half (51%) of 14 to 17-year-olds in the U.S. worry about school shootings and nearly six in ten report that they “have recently thought about what would happen if a person with a gun entered” their school or a school nearby.^42^

Further, students exposed to school shootings experience “declines in health and well-being, engage in more risky behaviors, and have worse education and labor market outcomes as young adults” according to a recent study using data on shootings compiled by the Center for Homeland Defense and Security.^43^ Researchers have found that local exposure to fatal school shootings is associated with a 21.4% increase in youth antidepressant use in the following 2 years.^44^ Evidence suggests an increased risk of suicide or accidental deaths among students affected by the Columbine High School shooting, particularly for boys.^45^

Additionally, exposure to shooting incidents in schools is associated with increased odds of adolescents avoiding school because of feeling unsafe. For example, high school students who are exposed to a school shooting have 20% greater odds of avoiding school because of feeling unsafe compared to those who have not been exposed.^46^ After the tragedy at Columbine High School, the percentage of students around the country who reported missing school because of safety concerns more than doubled in the months following the shooting.^47^

Researchers have found that local exposure to fatal school shootings is associated with a 21.4% increase in youth antidepressant use in the following 2 years.^44^

When discussing the mental health impacts of violence exposure on children, there is a strong body of literature supporting the impact on childhood development. Specifically, childhood exposure to witnessing firearm-related incidents has been associated with higher odds of adolescent handgun carrying.^48^ As children age, cumulative exposure to firearm violence and other traumatic experiences may impact development and contribute to mental and behavioral problems.^49^ As reported in the 2030 Healthy People Report, “children and adolescents exposed to violence are at risk for poor long-term behavioral and mental health outcomes, such as depression, anxiety, and post-traumatic stress disorder, regardless of whether they are victims, direct witnesses, or hear about the crime.”^50^

Certain groups experience disproportionate impacts from firearm violence exposure. For example, among youth living in large U.S. cities, Black and Hispanic/Latino youth were up to 7 times more likely to experience (firsthand and proximity to) a past-year firearm homicide than White youth, and on average experienced incidents closer to home.^51^

## Impact on Families

Research demonstrates that siblings of children and adolescents who died from firearm injury exhibited a 2.3-fold increase in psychiatric disorders, mothers exhibited a 3.6-fold increase, and fathers exhibited a 5.3-fold increase, as compared to families who did not experience firearm fatalities.^35^ Further, parents of children and adolescents who died from a firearm injury used more mental health services: 15.3-fold higher for mothers and 86.6-fold higher for fathers, compared to parents who did not lose a child to firearm violence.^35^

Family members of survivors of firearm violence also experience increased risk of mental health challenges. Specifically, there was a 12% increase in psychiatric disorders (including anxiety, mood disorders, psychosis, and other disorders) among family members (including spouses, children, parents, and other dependents) of individuals who survived a firearm injury compared to control participants who did not have a family member injured by firearm violence.^36^ In another study, mothers of children and adolescents who survived a firearm injury experienced a 75% increase in mental health visits compared to non-affected mothers.^35^ The same study found that parents of children and adolescents who survived a firearm-related injury experienced about a 30% increase in psychiatric disorders compared to control participants.^35^

Further, a separate study found that mothers who witness at least one shooting in their neighborhood or local community exhibit more symptoms of depression and are more likely to meet criteria for depression than mothers who do not witness a shooting.^52^

While far too many parents lose children to firearm violence, children are also losing parents. Between 1999 and 2020, a cross-sectional study estimated that 434,000 youth (<18 years old) experienced a firearm-related parental death.^53^ Black youth in this study experienced a disproportionate impact of parental deaths, primarily due to firearm-related deaths among fathers.^53^ Adverse childhood experiences, which may include the homicide or suicide of a parent, can be associated with lifelong negative effects on health (e.g., depression, heart disease, and cancer) and life opportunities, like education and job potential of children.^54^ As firearm-related injuries and deaths increase, the grief, trauma and risk of mental health challenges for children and family members of victims increases too.

Between 1999 and 2020, a cross-sectional study estimated that 434,000 youth (<18 years old) experienced a firearm-related parental death.^53^

FIGURE 5 Firearm violence leads to cascading harm across society

Firearms are the leading cause of death for children and adolescents

i In the scientific literature, exposure to firearm violence may range from being directly injured or witnessing firearm violence to living in a community affected by such violence or encountering these incidents on the news or social media.