# Acknowledgments

This report was prepared by the U.S. Department of Health and Human Services under the general direction of the Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health.

Vice Admiral (VADM) Vivek H. Murthy, M.D., M.B.A., Surgeon General, Office of the Surgeon General, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Thomas R. Frieden, M.D., M.P.H., Director, Centers for Disease Control and Prevention, Atlanta, Georgia.

Ursula E. Bauer, Ph.D., M.P.H., Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Dana Shelton, M.P.H., Deputy Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Peter A. Briss, M.D., M.P.H., Medical Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Rachel Kaufmann, Ph.D., M.P.H., Associate Director for Science, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Corinne Graffunder, Dr.P.H., M.P.H., Director, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

## Editors of the report were

- Cheryl L. Perry, Ph.D., Senior Scientific Editor, Professor and Regional Dean, The Rockwell Distinguished Chair in Society and Health, The University of Texas Health Science Center at Houston (UTHealth) School of Public Health, Austin, Texas.
- Melissa Harrell, Ph.D., M.P.H., Senior Scientific Editor, Associate Professor, Department of Health Promotion and Behavioral Sciences and the Michael & Susan Dell Center for Healthy Living, The University of Texas Health Science Center at Houston (UTHealth) School of Public Health, Austin, Texas.
- MeLisa R. Creamer, Ph.D., M.P.H., Senior Scientific Editor, Faculty Associate, Department of Health Promotion and Behavioral Sciences and the Michael & Susan Dell Center for Healthy Living, The University of Texas Health Science Center at Houston (UTHealth) School of Public Health, Austin, Texas.
- Steven Kelder, Ph.D., Senior Scientific Editor, Beth Toby Grossman Distinguished Professor of Spirituality and Healing; Associate Regional Dean; Co-Director, Michael & Susan Dell Center for Healthy Living; Professor, Division of Epidemiology, Human Genetics, and Environmental Sciences, The University of Texas Health Science Center at Houston (UTHealth) School of Public Health, Austin, Texas.
- Brian King, Ph.D., Senior Associate Editor, Deputy Director for Research Translation, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Leslie A. Norman, M.B.A., Managing Editor, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Peter L. Taylor, M.B.A., Technical Editor, Fairfax, Virginia.

## Contributing editors were

- Thomas Eissenberg, Ph.D., Director, Center for the Study of Tobacco Products; Professor of Psychology (Health Program), College of Humanities and Sciences and Member Scientist, Massey Cancer Center, Virginia Commonwealth University, Richmond, Virginia.
- Rachel A. Grana, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Pamela Ling, M.D., M.P.H., Professor, Division of General Internal Medicine, Department of Medicine, Center for Tobacco Control Research and Education, University of California, San Francisco, California.
- Mark Parascandola, Ph.D., M.P.H., Epidemiologist, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Jennifer L. Pearson, Ph.D., M.P.H., Research Investigator, The Schroeder Institute for Tobacco Research and Policy Studies at Truth Initiative, Washington, D.C.; Adjunct Assistant Professor, Department of Health, Behavior, and Society, Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.
- Jonathan M. Samet, M.D., M.S., Distinguished Professor and Flora L. Thornton Chair, Department of Preventive Medicine, Keck School of Medicine; Director, Institute for Global Health, University of Southern California, Los Angeles, California.
- Andrea C. Villanti, Ph.D., M.P.H., Director for Regulatory Science and Policy, The Schroeder Institute for Tobacco Research and Policy Studies at Truth Initiative, Washington, D.C.; Adjunct Assistant Professor, Department of Health, Behavior, and Society, Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.

## Contributing authors were

- Melissa D. Blank, Ph.D., Assistant Professor, Department of Psychology, West Virginia University, Morgantown, West Virginia.
- Frank J. Chaloupka, Ph.D., Director, Health Policy Center, Institute for Health Research and Policy, and Distinguished Professor, Department of Economics, University of Illinois at Chicago, Chicago, Illinois.
- Shari P. Feirman, Ph.D., M.S., Project Director for Regulatory Science and Policy, The Schroeder Institute for Tobacco Research and Policy Studies at Truth Initiative, Washington, D.C.
- Jonathan Foulds, Ph.D., Professor, Departments of Public Health Sciences and Psychiatry, College of Medicine, Penn State University, Hershey, Pennsylvania.
- Allison M. Glasser, M.P.H., Senior Project Manager, The Schroeder Institute for Tobacco Research and Policy Studies at Truth Initiative, Washington, D.C.
- Maciej L. Goniewicz, Ph.D., Pharm.D., Assistant Professor of Oncology, Department of Health Behavior, Roswell Park Cancer Institute, Buffalo, New York.
- Rachel A. Grana, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Lisa Henriksen, Ph.D., Senior Research Scientist, Stanford Prevention Research Center, Department of Medicine, School of Medicine, Stanford University, Palo Alto, California.
- Jidong Huang, Ph.D., Senior Research Scientist, Institute for Health Research and Policy, University of Illinois at Chicago, Chicago, Illinois.
- Lauren K. Katz, M.P.H., Research Associate I, The Schroeder Institute for Tobacco Research and Policy Studies at Truth Initiative, Washington, D.C.
- Frances Leslie, Ph.D., Vice Provost for Graduate Education; Dean of the Graduate Division; Professor of Pharmacology and Anatomy and Neurobiology, University of California, Irvine, California.
- M. Jane Lewis, Dr.Ph., Associate Professor, Health Education and Behavioral Science and Center for Tobacco Studies, School of Public Health, Rutgers University, New Brunswick, New Jersey.
- Kristy Marynak, M.P.P., Public Health Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Mark Parascandola, Ph.D., M.P.H., Epidemiologist, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Terry F. Pechacek, Ph.D., Professor and Interim Division Director of Health Management and Policy, School of Public Health, Georgia State University, Atlanta, Georgia.
- Gabbi Promoff, M.A., Associate Director for Policy, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Kurt M. Ribisl, Ph.D., Professor, Department of Health Behavior, University of North Carolina Gillings School of Global Public Health; Program Leader in Cancer Prevention and Control, University of North Carolina Lineberger Comprehensive Cancer Center, Chapel Hill, North Carolina.
- April Roeseler, B.S.N., M.S.P.H., Chief, California Tobacco Control Program, California Department of Public Health, Sacramento, California.
- Jonathan M. Samet, M.D., M.S., Distinguished Professor and Flora L. Thornton Chair, Department of Preventive Medicine, Keck School of Medicine; Director, Institute for Global Health, University of Southern California, Los Angeles, California.
- Laura R. Stroud, Ph.D., Senior Research Scientist, Centers for Behavioral and Preventive Medicine, The Miriam Hospital; Associate Professor, Department of Psychiatry and Human Behavior, Alpert Medical School, and Department of Behavioral and Social Sciences, School of Public Health, Brown University, Providence, Rhode Island.
- Prue Talbot, Ph.D., Director, University of California, Riverside Stem Cell Center and Core; Professor of Cell Biology, Department of Cell Biology and Neuroscience, University of California, Riverside, California.
- Mark Travers, Ph.D., M.S., Assistant Professor of Oncology, Department of Health Behavior and Air Pollution Exposure Research Laboratory, Roswell Park Cancer Institute, Buffalo, New York.
- Scott Weaver, Ph.D., M.A., Assistant Professor, Division of Epidemiology and Biostatistics, School of Public Health, Georgia State University, Atlanta, Georgia.

## Reviewers were

- David B. Abrams Ph.D., Executive Director, The Schroeder Institute for Tobacco Research and Policy Studies at Truth Initiative, Washington, D.C.; Professor, Department of Health, Behavior, and Society, Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland; Professor of Oncology, Georgetown University Medical Center, Lombardi Comprehensive Cancer Center (adjunct), Washington, D.C.
- Heather Rubino Althouse, Senior Regulatory Counsel, Office of Compliance and Enforcement, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- René A. Arrazola, M.P.H., Epidemiologist, Epidemiology Branch, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- David L. Ashley, Ph.D., Director, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Cathy L. Backinger, Ph.D., M.P.H., Deputy Director for Research, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Tracey E. Barnett, Ph.D., Associate Professor, Department of Epidemiology, College of Public Health and Health Professions and College of Medicine, University of Florida, Gainesville, Florida.
- Neal L. Benowitz, M.D., Professor of Medicine, Bioengineering, and Therapeutic Sciences, Chief, Division of Clinical Pharmacology, University of California, San Francisco, California.
- Jay M. Bernhardt, Ph.D., M.P.H., Interim Dean and Professor, Moody College of Communication; Founding Director, Center for Health Communication, The University of Texas, Austin, Texas.
- Nazleen Bharmal, M.D., Ph.D., M.P.P., Director of Science and Policy, Office of the Surgeon General, U.S. Department of Health and Human Services, Washington, D.C.
- Allan M. Brandt, Ph.D., Amalie Moses Kass Professor of the History of Medicine, Department of Global Health and Social Medicine, Harvard University Medical School, Boston, Massachusetts.
- April Brubach, M.A., Director, Division of Public Health Education, Office of Health Communication and Education, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Priscilla Callahan-Lyon, M.D., Medical Branch Chief, Division of Individual Health Science, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Frank J. Chaloupka, Ph.D., Director, Health Policy Center, Institute for Health Research and Policy; Distinguished Professor, Department of Economics, University of Illinois at Chicago, Chicago, Illinois.
- Ii-Lun Chen, M.D., Director, Division of Individual Health Science, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Beverly Chernaik, J.D., Director, Office of Regulations, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Joanna E. Cohen, Ph.D., Director, Institute for Global Tobacco Control; Bloomberg Professor of Disease Prevention, Department of Health, Behavior, and Society, Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.
- Catherine G. Corey, M.S.P.H., Epidemiologist, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Kathleen Crosby, Director, Office of Health Communication and Education, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Cristine D. Delnevo, Ph.D., M.P.H., Professor and Director, Center for Tobacco Studies, Rutgers School of Public Health, New Brunswick, New Jersey.
- Lauren M. Dutra, Sc.D., M.A., Postdoctoral Fellow, Center for Tobacco Control Research and Education, University of California, San Francisco, California.
- Lucinda J. England, M.D., M.S.P.H., Medical Officer, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Michael P. Eriksen, Sc.D., Sc.M., Dean and Regents’ Professor, Division of Health Management and Policy, School of Public Health, Georgia State University, Atlanta, Georgia.
- Michael C. Fiore, M.D., M.P.H., M.B.A., University of Wisconsin Hilldale Professor of Medicine; Director, Center for Tobacco Research and Intervention, University of Wisconsin School of Medicine and Public Health, Madison, Wisconsin.
- Neal D. Freedman, Ph.D., M.P.H., Senior Investigator, Metabolic Epidemiology Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Elizabeth M. Ginexi, Ph.D., Program Director, Tobacco Control Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Gary A. Giovino, Ph.D., M.S., Professor and Chair, Department of Community Health and Health Behavior, School of Public Health and Health Professions, University at Buffalo, The State University of New York, Buffalo, New York.
- Stanton A. Glantz, Ph.D., Professor of Medicine and American Legacy Foundation Distinguished Professor in Tobacco Control; Director, Center for Tobacco Control Research and Education, University of California, San Francisco, California.
- Maciej L. Goniewicz, Ph.D., Pharm.D., Assistant Professor of Oncology, Department of Health Behavior, Roswell Park Cancer Institute, Buffalo, New York.
- Rachel A. Grana, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Bonnie Halpern-Felsher, Ph.D., FSAHM, Director of Research, Professor, Division of Adolescent Medicine, Stanford University, Palo Alto, California.
- Dorothy K. Hatsukami, Ph.D., Forster Family Professor in Cancer Prevention, Masonic Cancer Center, University of Minnesota, Minneapolis, Minnesota.
- Corinne Husten, M.D., M.P.H., Senior Medical Advisor, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Frances Jensen, M.D., F.A.C.P., Professor and Chair, Neurology Department, Perelman School of Medicine, University of Pennsylvania, Philadelphia, Pennsylvania.
- Ronald L. Johnson, Ph.D., Program Director, DNA and Chromosome Aberrations Branch, Division of Cancer Biology, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Sarah E. Johnson, Ph.D., Social Scientist, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Annette R. Kaufman, Ph.D., M.P.H., Health Scientist and Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Ryan David Kennedy, Ph.D., Assistant Professor, Institute for Global Tobacco Control, Department of Health, Behavior, and Society, Bloomberg School of Public Health, Johns Hopkins University, Baltimore, Maryland.
- Jonathan D. Klein, M.D., M.P.H., F.A.A.P., Associate Executive Director; Director, Julius B. Richmond Center, American Academy of Pediatrics, Elk Grove Village, Illinois.
- Suchitra Krishnan-Sarin, Ph.D., Professor, Department of Psychiatry, School of Medicine, Yale University, New Haven, Connecticut.
- Lauren K. Lempert, J.D., M.P.H., Associate Specialist, Center for Tobacco Control Research and Education, University of California, San Francisco, California.
- Maggie Mahoney, J.D., Executive Director, Tobacco Control Legal Consortium at the Public Health Law Center, St. Paul, Minnesota.
- Tim McAfee, M.D., Medical Officer, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Daniel McGoldrick, M.A., Vice President, Global Health Advocacy Incubator, Campaign for Tobacco-Free Kids, Washington, D.C.
- Cindy Miner, Ph.D., Associate Director for Scientific Communication, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Matthew L. Myers, J.D., President, Campaign for Tobacco-Free Kids, Washington, D.C.
- Linda J. Neff, Ph.D., Senior Epidemiologist, Epidemiology Branch, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Richard J. O’Connor, Ph.D., Member and Professor of Oncology, Department of Health Behavior, Division of Cancer Prevention and Population Sciences, Roswell Park Cancer Institute, Buffalo, New York.
- Mark Parascandola, Ph.D., M.P.H., Epidemiologist, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Terry F. Pechacek, Ph.D., Professor and Interim Division Director of Health Management and Policy, School of Public Health, Georgia State University, Atlanta, Georgia.
- Alexander Persoskie, Ph.D., Social Scientist, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- John P. Pierce, Ph.D., Professor Emeritus, Department of Family Medicine and Public Health and the Moores Cancer Center, University of California, San Diego, La Jolla, California.
- David W. Racine, M.S., Senior Program Management Officer, Office of Compliance and Enforcement, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Chad J. Reissig, Ph.D., Addiction Branch Chief, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Joelle Robinson, M.P.H., Social Scientist, Office of Science, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Jonathan M. Samet, M.D., M.S., Distinguished Professor and Flora L. Thornton Chair, Department of Preventive Medicine, Keck School of Medicine; Director, Institute for Global Health, University of Southern California, Los Angeles, California.
- Peter G. Shields, M.D., Deputy Director, Comprehensive Cancer Center, James Cancer Hospital; Professor, College of Medicine, The Ohio State University, Columbus, Ohio.
- Ann Simoneau, J.D., M.B.A., Director, Office of Compliance and Enforcement, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.
- Theodore A. Slotkin, Ph.D., Professor, Department of Pharmacology and Cancer Biology, Duke University Medical Center, Durham, North Carolina.
- Anne Sowell, Ph.D., Health Scientist, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Erin L. Sutfin, Ph.D., Associate Professor and Vice Chair, Department of Social Sciences and Health Policy, Division of Public Health Sciences, Wake Forest School of Medicine, Wake Forest University, Winston-Salem, North Carolina.
- Robert E. Vollinger, Jr., M.S.P.H., (Dr.P.H. Candidate), Program Director and Public Health Advisor, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Kenneth E. Warner, Ph.D., Avedis Donabedian Distinguished University Professor of Public Health, Department of Health Management and Policy, University of Michigan School of Public Health, Ann Arbor, Michigan.
- Geoffrey Ferris Wayne, M.A., Research Consultant, Sebastopol, California.
- Deborah M. Winn, Ph.D., Deputy Director, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Rockville, Maryland.
- Mitchell Zeller, J.D., Director, Center for Tobacco Products, U.S. Food and Drug Administration, Silver Spring, Maryland.

## Other contributors were

- Katherine J. Asman, M.S.P.H., Statistician, Biostatistics and Epidemiology Division, RTI International, Atlanta, Georgia.
- Adam J. Burke, M.A., Research Associate Lead, The Monitoring the Future Study, University of Michigan, Ann Arbor, Michigan.
- Dayana Chanson, M.P.H., Research Associate to Jonathan M. Samet, M.D., M.S., Department of Preventive Medicine, Keck School of Medicine, University of Southern California, Los Angeles, California.
- Tara Christine Chu, M.P.H., Research Associate to Jonathan M. Samet, M.D., M.S., Department of Preventive Medicine, Keck School of Medicine, University of Southern California, Los Angeles, California.
- Stephanie L. Clendennen, M.P.H., Predoctoral Fellow, Tobacco Center of Regulatory Science on Youth and Young Adults, The University of Texas Health Science Center at Houston (UTHealth) School of Public Health, Austin, Texas.
- Sarah J. Cross, Graduate Student Researcher, Department of Anatomy and Neurobiology, University of California, Irvine, California.
- Nicholas J. Felicione, Graduate Research Assistant, Department of Psychology, West Virginia University, Morgantown, West Virginia.
- Kyle R. Gregory, J.D., M.S.H.A., Postdoctoral Research Associate, Tobacco Center of Regulatory Science, School of Public Health, Georgia State University, Atlanta, Georgia.
- Emily T. Hébert, M.P.H., Doctoral Student, Michael & Susan Dell Center for Healthy Living, The University of Texas Health Science Center at Houston (UTHealth) School of Public Health, Austin, Texas.
- Erin O’Connor Landau, M.S., Data Analyst, DB Consulting Group (Contractor), Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Pamela Lemos, M.S., Public Health Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Gerald V. [Simon] McNabb, Lead Public Health Analyst, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Washington, D.C.
- Ronald L. Johnson, Ph.D., Program Director, DNA and Chromosome Aberrations Branch, Division of Cancer Biology, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.
- Hoda S. Magid, M.H.S., Center for Tobacco Control Research and Education, University of California, San Francisco, California.
- Dale Mantey, M.P.A., Predoctoral Fellow, Tobacco Center of Regulatory Science on Youth and Young Adults, The University of Texas Health Science Center at Houston (UTHealth) School of Public Health, Austin, Texas.
- Mandie Mills, Photographer, Office of the Associate Director for Communication, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Richard Miech, Ph.D., Professor, Institute for Social Research, University of Michigan, Ann Arbor, Michigan.
- Luz M. Moncayo, Executive Assistant to Jonathan M. Samet, M.D., M.S., Department of Preventive Medicine, Keck School of Medicine, Institute for Global Health, University of Southern California, Los Angeles, California.
- Maureen O’Brien, J.D., Staff Attorney, Tobacco Control Legal Consortium at the Public Health Law Center, St. Paul, Minnesota.
- Patrick M. O’Malley, Ph.D., Research Professor, Survey Research Center, Institute for Social Research, University of Michigan, Ann Arbor, Michigan.
- Gabriela V. Portillo, Masters Student, Michael & Susan Dell Center for Healthy Living, The University of Texas Health Science Center at Houston (UTHealth) School of Public Health, Austin, Texas.
- Anna Teplinskaya, M.D., M.P.H., Public Health Analyst, Epidemiology Branch, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Tenecia Smith, M.P.H., Data Analyst, DB Consulting Group (Contractor), Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Kathryn E. Szynal, Editorial Assistant, McNeal Professional Services (Contractor), Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Teresa Wang, Ph.D., M.S., Epidemic Intelligence Service Officer, Lieutenant, U.S. Public Health Service, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.
- Jennifer Whitmill, M.P.H., Data Analyst, DB Consulting Group (Contractor), Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia