# List of Abbreviations

α4β2: alpha 4 beta 2-nicotinic acetylcholine receptor subtype
α7: alpha 7 nicotinic acetylcholine receptor subtype
α6: alpha 6 nicotinic acetylcholine receptor subtype
µg: microgram
5AP tLTP protocol: 5 action potential timing-dependent long-term potentiation protocol
5-CSRTT: 5-choice serial reaction time task
5-HIAA: 5-hydroxyindole acetic acid, the primary metabolite of serotonin
5-HT_1AR_: serotonin (5-hydroxytryptamine) receptor 1A
5-HT_2A/C_: serotonin (5-hydroxytryptamine) receptor 2 A/C
86Rb+ efflux assay: measure of nicotinic acetylcholine receptor function via rubidium-86 ion efflux [125-I]α-Btx binding measurement of binding at α7 nAChRs using the antagonist alpha-bungarotoxin
[^125^I]α-CtxMII binding: measurement of binding at α6 nAChRs using the antagonist alpha-conotoxin MII
[^125^I]A-85380 binding: measurement of binding at α4β2 nAChRs using the agonist A-85380
A1: primary auditory cortex
AAP: American Academy of Pediatrics
ACR: American Association of Cancer Research
AARC: American Association for Respiratory Care
ACP: American College of Physicians
ACS: American Cancer Society
ADHD: attention deficit hyperactivity disorder
ADI: acceptable daily intake
AEMSA: American E-Liquid Manufacturing Standards Association
AHA: American Heart Association
AMPA: α-amino-3-hydroxy-5-methyl-4-isoxazolepropionic acid
AMPAR: AMPA receptor
ANHCS: Annenberg National Health Communication Survey
ANR: Americans for Nonsmokers’ Rights
AOR: adjusted odds ratio
AP: acetyl propionyl
APA: American Psychiatric Association
APV: advanced personal vaporizers
arc: activity-regulated cytoskeleton-associated protein
ATF: U.S. Department of Justice, Bureau of Alcohol, Tobacco, Firearms and Explosives
A-V: atrial-ventricular
AVA: American Vaping Association
BART: Balloon Analogue Risk Task
BCAP/CAP: Committees of Advertising Practice (UK)
BLA: basolateral amygdala
BNST: bed nucleus of the stria terminalis
BOP: Bureau of Prisons
BP: blood pressure
CAD: cinnamaldehyde
CAM: cell-adhesion molecule
cAMP-PKA: cyclic AMP-protein kinase A, signaling cascade
CARDIA: Coronary Artery Risk Development in Young Adults
CASAA: Consumer Advocates for Smoke-free Alternatives Association
CCTA: Contraband Cigarette Trafficking Act
CDC: Centers for Disease Control and Prevention
CDER: Center for Drug Evaluation and Research
C-DISC-IV: Diagnostic Interview for Children−Version 4
cFos: protooncogene and immediate early gene used as a marker of neuronal activity
CFR: Code of Federal Regulations
CI: confidence interval
CMS: Centers for Medicare & Medicaid Services
CO_2_: carbon dioxide
COMDTINST: Commandant Instruction
CPP: conditioned place preference
CPu: caudate putamen
CREB: cAMP response element-binding protein
CRF: corticotropin-releasing factor
CRP: C-reactive protein
CSI: Child Symptom Inventory
CTA: conditioned taste aversion
CTP: Center for Tobacco Products
D1R: dopamine D1 receptor
DA: diacetyl
DA: dopamine
DAT1: dopamine regulation genotype
DEHP: diethylhexyl phthalate
DEP: diethyl phthalate
DHS: U.S. Department of Homeland Security
DISC-YC: Diagnostic Interview Schedule for Children-Parent Scale-Young Child
DoD: U.S. Department of Defense
DOPAC: 3,4-dihydroxyphenylacetic acid, metabolite of dopamine
DOT: U.S. Department of Transportation
DSM-III: Diagnostic and Statistical Manual of Mental Disorders, 3rd Edition
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, 4th Edition
EC: electronic cigarette
ECIG Inc.: Electronic Cigarette Industry Group, Inc.
ECIG Ltd.: Electronic Cigarettes International Group, Ltd.
ED: U.S. Department of Education
ENDS: electronic nicotine delivery systems
ENNDS: electronic non-nicotine delivery systems
EOP: Executive Office of the President
EPA: U.S. Environmental Protection Agency
ERS: European Respiratory Society
EPSC: excitatory postsynaptic current
EPSDT: Early and Periodic Screening, Diagnosis and Treatment
EPSP: excitatory postsynaptic potential
ESD: electronic smoking device
EU: European Union
F1: first filial generation (and similar)
FAA: Federal Aviation Administration
FCC: Federal Communications Commission
FCLAA: Federal Cigarette Labeling and Advertising Act
FCTC: Framework Convention on Tobacco Control
FD&C Act: Federal Food, Drug, and Cosmetic Act
FDA: U.S. Food and Drug Administration
FEF: forced expiratory flow
FeNO: exhaled nitric oxide
FEV_1_: forced expiratory volume in 1 second
fMRI: functional magnetic resonance imaging
FR: fixed ratio
FST: forced swim test
FTC: U.S. Federal Trade Commission
FVC: forced vital capacity
FY: fiscal year
G20: gestational day 20 (and similar)
g: gram
GABA: gamma-aminobutyric acid
GABAergic: any cell, especially any neuron, that releases GABA
GPCR: G-protein-coupled-receptor
GSA: General Services Administration
GTP: guanosine triphosphate
GTPase: large family of hydrolase enzymes that can bind and hydrolyze GTP
HONC: Hooked on Nicotine Checklist
HPLC-ECD: high-performance liquid chromatography electrochemical detection
HUD: U.S. Department of Housing and Urban Development
HVA: homovanillic acid
IARC: International Agency for Research on Cancer
ICD-10: International Statistical Classification of Diseases and Related Health Problems, 10th revision
ICE: Bureau of Immigration and Customs Enforcement
ICR mice: Institute for Cancer Research strain of mice
ICSS: intracranial self-stimulation
IOM: Institute of Medicine
i.p.: intraperitoneal
IQ: intelligence quotient
IRC: Internal Revenue Code
i.v.: intravenous
kg: kilogram
KO: knockout
L: liter
L&M: Liggett & Myers
LC-MS/MS: liquid chromatography-tandem mass spectrometry
LH: lateral hypothalamus
M&As: mergers, formations of partnerships, and acquisitions
m^2^: square meter
m^3^: cubic meter
MAOA: monoamine oxidase A
MAPK: mitogen-activated protein kinase
MCH: melanin-concentrating hormone
mFTQ: modified Fagerström Tolerance Questionnaire
mg: milligram
mGluR2: metabotropic glutamate receptor 2
mL: milliliter
mPFC: medial prefrontal cortex
mRNA: messenger ribonucleic acid
MSN: medium spiny neuron
MTF: Monitoring the Future
NAB: N-nitrosoanabasine
N_2_: nitrogen
NAc: nucleus accumbens
NACDA: National Advisory Council on Drug Abuse
nAChR: nicotinic acetylcholine receptor
NAc-shell: nucleus accumbens shell
NAT: N-nitrosoanatabine
NATS: National Adult Tobacco Survey
NCI: National Cancer Institute
NDAA: National Defense Authorization Act
NDSS: Nicotine Dependence Syndrome Scale
NE: norepinephrine
ng: nanogram
NGFI-B: nerve growth factor-induced gene-B
NHANES III: Third National Health and Nutrition Examination Survey
NHSDA: National Household Survey on Drug Abuse
NIH: National Institutes of Health
NMDAR: N-methyl-D-aspartate receptor
NIDA: National Institute on Drug Abuse
NIOSH: National Institute for Occupational Safety
NJYTS: New Jersey Youth Tobacco Survey
NLSY: National Longitudinal Survey of Youth
nm: nanometer
NNN: N-nitrosonornicotine
NNK: 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone
NRT: nicotine replacement therapy
NYS: New York State Follow-Up
NYTS: National Youth Tobacco Survey
O_2_: oxygen
ODD: oppositional defiant disorder
OMB: Office of Management and Budget
OPM: Office of Personnel Management
OR: odds ratio
OSH: Office on Smoking and Health
OSHA: U.S. Department of Labor, Occupational Safety and Health Administration
P3 (and similar): postnatal day number
PACT: Prevent All Cigarette Trafficking Act
PAH: polycyclic aromatic hydrocarbon
PATH: Population Assessment of Tobacco and Health
PDAY: Pathological Determinants of Atherosclerosis in Youth
PFC: prefrontal cortex
PHS: Public Health Service
PIH: Public and Indian Housing
PVN: paraventricular nucleus of the thalamus
PG: propylene glycol
PM: particulate matter
PM_2.5_: fine particulate matter
PNE: prenatal nicotine exposure
p.o.: per os (by mouth)
Postn: periostin, osteoblast-specific factor
PR: progressive ratio
PREP: potential reduced-exposure product
PVN: paraventricular nucleus of the thalamus
qRT-PCR: quantitative real-time polymerase chain reaction
RCRA: Resource Conservation and Recovery Act
SAC: saccharin
SAMHSA: Substance Abuse and Mental Health Services Administration
s.c.: subcutaneous
SCAN: Screening test for Auditory Processing Disorders
SD: standard deviation
SE: standard error
sec: seconds
SEC: Securities and Exchange Commission
SES: socioeconomic status
SFATA: Smoke Free Alternatives Trade Association
SIDS: sudden infant death syndrome
SMC: serial multiple choice
SNAP: Special Supplemental Nutrition Program
SNP: single-nucleotide polymorphism
SRITA: Stanford Research into the Impact of Tobacco Advertising
STOP: Smuggled Tobacco Prevention Act
TCR: trigeminocardiac reflex
TEOAEs: transient evoked otoacoustic emissions
TH: tyrosine hydroxylase
THC: tetrahydrocannabinol
TSNA: tobacco-specific nitrosamine
TTB: U.S. Department of Treasury, Alcohol and Tobacco Tax and Trade Bureau
TVECA: Tobacco Vapor Electronic Cigarette Association
UK: United Kingdom
U.S.C.: U.S. Code
USDA: U.S. Department of Agriculture
USDHEW: U.S. Department of Health, Education, and Welfare
USDHHS: U.S. Department of Health and Human Services
USP: U.S. Pharmacopeia
USTR: U.S. Trade Representative
V: voltage
VA: U.S. Department of Veterans Affairs
VG: vegetable glycerin
VOC: volatile organic compound
VTA: ventral tegmental area
WHO: World Health Organization
WIC: Women, Infants, and Children
Wnt: Wingless-Type MMTV Integration Site Family, member 1, intracellular signaling factors
WT: wild type
w/v: weight/volume
YRBSS: Youth Risk Behavior Surveillance System