# References

1 Lomas A, Leonardi-Bee J, Bath-Hextall F. A systematic review of worldwide incidence of nonmelanoma skin cancer. Br J Dermatol. 2012;166(5):1069-1080. [pmid: 22251204].
2 Rogers HW, Weinstock MA, Harris AR, et al. Incidence estimate of nonmelanoma skin cancer in the United States, 2006. Arch Dermatol. 2010;146(3):283-287. [pmid: 20231499].
3 Armstrong BK, Kricker A. The epidemiology of UV induced skin cancer. J Photochem Photobiol B. 2001;63:8-18. [pmid: 11684447].
4 Burdon-Jones D, Thomas P, Baker R. Quality of life issues in nonmetastatic skin cancer. Br J Dermatol. 2010;162(1):147-151. [pmid: 19796177].
5 Lewis KG, Weinstock MA. Nonmelanoma skin cancer mortality (1988-2000): the Rhode Island follow-back study. Arch Dermatol. 2004;140(7):837-842. [pmid: 15262694].
6 Pollack LA, Li J, Berkowitz Z, et al. Melanoma survival in the United States, 1992 to 2005. J Am Acad Dermatol. 2011;65(5 suppl 1):S78.e01-S78.e10. [pmid: 22018071].
7 Machlin S, Carper K, Kashihara D. Health care expenditures for non-melanoma skin cancer among adults, 2005–2008 (average annual). Statistical Brief #345. Rockville, MD. Agency for Healthcare Research and Quality. 2011. http://www.meps.ahrq.gov/mepsweb/data_files/publications/st345/stat345.shtml. January 16, 2014.
8 Stern RS. Prevalence of a history of skin cancer in 2007: results of an incidence-based model. Arch Dermatol. 2010;146(3):279-282. [pmid: 20231498].
9 Jemal A, Saraiya M, Patel P, et al. Recent trends in cutaneous melanoma incidence and death rates in the United States, 1992-2006. J Am Acad Dermatol. 2011;65(5 suppl 1):S17.e01-S17.e11. [pmid: 22018063].
10 Medical Expenditure Panel Survey. Rockville, MD. Agency for Healthcare Research and Quality. http://meps.ahrq.gov/mepsweb/data_stats/download_data_files.jsp. January 2014.
11 U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999–2010 Incidence and Mortality Web-based report. Atlanta, GA. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services and National Cancer Institute, National Institutes of Health. 2013. http://www.cdc.gov/uscs. January 20, 2014.
12 Weir HK, Marrett LD, Cokkinides V, et al. Melanoma in adolescents and young adults (ages 15-39 years): United States, 1999-2006. J Am Acad Dermatol. 2011;65(5 suppl 1):S38-S49. [pmid: 22018066].
13 Christenson LJ, Borrowman TA, Vachon CM, et al. Incidence of basal cell and squamous cell carcinomas in a population younger than 40 years. JAMA. 2005;294(6):681-690. [pmid: 16091570].
14 Jemal A, Simard EP, Dorell C, et al. Annual report to the nation on the status of cancer, 1975-2009, featuring the burden and trends in human papillomavirus(HPV)-associated cancers and HPV vaccination coverage levels. J Natl Cancer Inst. 2013;105(3):175-201. [pmid: 23297039].
15 Diepgen TL, Mahler V. The epidemiology of skin cancer. Br J Dermatol. 2002;146(suppl 61):1-6. [pmid: 11966724].
16 Garbe C, Leiter U. Melanoma epidemiology and trends. Clin Dermatol. 2009;27(1):3-9. [pmid: 19095149].
17 Godar DE. Worldwide increasing incidences of cutaneous malignant melanoma. J Skin Cancer. 2011;2011:858425. [pmid: 22007306].
18 Gandini S, Sera F, Cattaruzza MS, et al. Meta-analysis of risk factors for cutaneous melanoma: III. family history, actinic damage and phenotypic factors. Eur J Cancer. 2005;41(14):2040-2059. [pmid: 16125929].
19 Marcil I, Stern RS. Risk of developing a subsequent nonmelanoma skin cancer in patients with a history of nonmelanoma skin cancer: a critical review of the literature and meta-analysis. Arch Dermatol. 2000;136(12):1524-1530. [pmid: 11115165].
20 Balamurugan A, Rees JR, Kosary C, Rim SH, Li J, Stewart SL. Subsequent primary cancers among men and women with in situ and invasive melanoma of the skin. J Am Acad Dermatol. 2011;65(5 suppl 1):S69-S77. [pmid: 22018070].
21 Qureshi AA, Zhang M, Han J. Heterogeneity in host risk factors for incident melanoma and non-melanoma skin cancer in a cohort of U.S. women. J Epidemiol. 2011;21(3):197-203. [pmid: 21515942].
22 Chen T, Fallah M, Kharazmi E, Ji J, Sundquist K, Hemminki K. Effect of a detailed family history of melanoma on risk for other tumors: a cohort study based on the nationwide Swedish Family-Cancer Database. J Invest Dermatol. 2014;134(4):930-936. [pmid: 24192716].
23 Karagas MR, Stukel TA, Greenberg ER, Baron JA, Mott LA, Stern RS. Risk of subsequent basal cell carcinoma and squamous cell carcinoma of the skin among patients with prior skin cancer. Skin Cancer Prevention Study Group. JAMA. 1992;267(24):3305-3310. [pmid: 1597912].
24 Mitra D. An ultraviolet-radiation-independent pathway to melanoma carcinogenesis in the red hair/fair skin background. Nature. 2012;491:449-453. [pmid: 23123854].
25 Armstrong BK, Kricker A. How much melanoma is caused by sun exposure?. Melanoma Res. 1993;3(6):395-401. [pmid: 8161879].
26 Berwick M, Lachiewics A, Pestak C, Thomas N. Solar UV exposure and mortality from skin tumors. Reichrath J, editor. Sunlight, Vitamin D and Skin Cancer. New York, NY. Springer. 2008;624:117-124.
27 El Ghissassi F, Baan R, Straif K, et al. A review of human carcinogens—part D: radiation. Lancet Oncol. 2009;10(8):751-752. [pmid: 19655431].
28 Saraiya M, Glanz K, Briss P, Nichols P, White C, Das D. Preventing skin cancer: findings of the Task Force on Community Preventive Services on reducing exposure to ultraviolet light. MMWR Recomm Rep. 2003;52(RR-15):1-12. [pmid: 14561953].
29 Markovic SN, Erickson LA, Rao RD, et al. Malignant melanoma in the 21st century, part 1: epidemiology, risk factors, screening, prevention, and diagnosis. Mayo Clin Proc. 2007;82(3):364-380. [pmid: 17352373].
30 International Agency for Research on Cancer, World Health Organization. IARC Monographs on the Evaluation of Carcinogenic Risks to Humans. Part D: Solar and Ultraviolet Radiation. Lyon, France. International Agency for Research on Cancer. 2012;100D. http://monographs.iarc.fr/ENG/Monographs/vol100D/mono100D.pdf. December 3, 2013.
31 Eriksson H, Lyth J, Mansson-Brahme E, et al. Later stage at diagnosis and worse survival in cutaneous malignant melanoma among men living alone: a nationwide population-based study from Sweden. J Clin Oncol. 2014;32(13):1356-1364. [pmid: 24687828].
32 Gruber SB, Armstrong BK. Cutaneous and ocular melanoma. Schottenfeld D, Fraumeni JF, editors. Cancer Epidemiology and Prevention. New York, NY. Oxford University Press. 2006:1196-1229.
33 World Health Organization. Ultraviolet radiation and health. World Health Organization website. http://www.who.int/uv/uv_and_health/en/index.html. June 24, 2013.
34 U.S. Environmental Protection Agency, Office of Air and Radiation, SunWise Program. UV radiation. U.S. Environmental Protection Agency website. http://www.epa.gov/sunwise/doc/uvradiation.html. June 11, 2014.
35 Gilchrest BA. Molecular aspects of tanning. J Invest Dermatol. 2011;131:e14-e17. [pmid: 22094400].
36 Gilchrest BA, Eller MS. DNA photodamage stimulates melanogenesis and other photoprotective responses. J Investig Dermatol Symp Proc. 1999;4(1):35-40.
37 Gilchrest B, Eller M, Geller AC, Yaar M. The pathogenesis of melanoma induced by ultraviolet radiation. N Engl J Med. 1999;340(17):1341-1348. [pmid: 10219070].
38 Grinde B, Patil GG. Biophilia: does visual contact with nature impact on health and well-being?. Int J Environ Res Public Health. 2009;6(9):2332-2343. [pmid: 19826546].
39 Thompson Coon J, Boddy K, Stein K, Whear R, Barton J, Depledge MH. Does participating in physical activity in outdoor natural environments have a greater effect on physical and mental wellbeing than physical activity indoors? A systematic review. Environ Sci Technol. 2011;45(5):1761-1772. [pmid: 21291246].
40 Abraham A, Sommerhalder K, Abel T. Landscape and well-being: a scoping study on the health-promoting impact of outdoor environments. Int J Public Health. 2010;55(1):59-69. [pmid: 19768384].
41 Agelli M, Clegg LX, Becker JC, Rollison DE. The etiology and epidemiology of Merkel cell carcinoma. Curr Probl Cancer. 2010;34(1):14-37. [pmid: 20371072].
42 Hodgson NC. Merkel cell carcinoma: changing incidence trends. J Surg Oncol. 2005;89(1):1-4. [pmid: 15611998].
43 Karagas MR, Weinstock MA, Nelson HH. Keratinocyte carcinomas (basal and squamous cell carcinomas of the skin). Schottenfeld D, Fraumeni JF, editors. Cancer Epidemiology and Prevention. 3rd ed. New York, NY. Oxford University Press. 2006:1230-1250.
44 Surveillance, Epidemiology, and End Results (SEER) Program. Bethesda, MD. National Cancer Institute. SEER*Stat Database: Mortality - all COD, aggregated with state, total U.S. (1969-2010) <Katrina/Rita population adjustment>, National Cancer Institute, Division of Cancer Control and Population Sciences, Surveillance Research Program, Surveillance Systems Branch, released April 2013. Underlying mortality data provided by National Center for Health Statistics.
45 Karagas MR, Greenberg ER, Spencer SK, Stukel TA, Mott LA. Increase in incidence rates of basal cell and squamous cell skin cancer in New Hampshire, USA. New Hampshire skin cancer study group. Int J Cancer. 1999;81(4):555-559. [pmid: 10225444].
46 Harris RB, Griffith K, Moon TE. Trends in the incidence of nonmelanoma skin cancers in southeastern Arizona, 1985-1996. J Am Acad Dermatol. 2001;45(4):528-536. [pmid: 11568742].
47 Wu S, Han J, Li WQ, Li T, Qureshi AA. Basal-cell carcinoma incidence and associated risk factors in U.S. women and men. Am J Epidemiol. 2013;178(6):890-897. [pmid: 23828250].
48 Karia PS, Han J, Schmults CD. Cutaneous squamous cell carcinoma: estimated incidence of disease, nodal metastasis, and deaths from disease in the United States, 2012. J Am Acad Dermatol. 2013;68(6):957-966. [pmid: 23375456].
49 National Program of Cancer Registries (NPCR) and Surveillance, Epidemiology, and End Results (SEER) Program. Atlanta, GA. Centers for Disease Control and Prevention. Bethesda, MD. National Cancer Institute. Data from 2007–2011.
50 Surveillance, Epidemiology, and End Results (SEER) Program. Bethesda, MD. National Cancer Institute. SEER*Stat Database: Incidence - SEER 9 regs research data, nov 2011 sub (1973-2010) <Katrina/Rita population adjustment> - linked to county attributes - total U.S., 1969-2010 counties, National Cancer Institute, Division of Cancer Control and Population Sciences, Surveillance Research Program, Surveillance Systems Branch, released April 2013, based on the November 2012 submission.
51 Edwards BK, Noone AM, Mariotto AB, et al. Annual report to the nation on the status of cancer, 1975-2010, featuring prevalence of comorbidity and impact on survival among persons with lung, colorectal, breast, or prostate cancer. Cancer. 2014;120(9):1290-1314. [pmid: 24343171].
52 National Program of Cancer Registries (NPCR) and Surveillance, Epidemiology, and End Results (SEER) Program. Atlanta, GA. Centers for Disease Control and Prevention. Bethesda, MD. National Cancer Institute. Data from 2002–2011.
53 Watson M, Johnson CJ, Chen VW, et al. Melanoma surveillance in the United States: overview of methods. J Am Acad Dermatol. 2011;65(5 suppl 1):S6-S16. [pmid: 22018069].
54 Bradford PT, Anderson WF, Purdue MP, Goldstein AM, Tucker MA. Rising melanoma incidence rates of the trunk among younger women in the United States. Cancer Epidemiol Biomarkers Prev. 2010;19(9):2401-2406. [pmid: 20826837].
55 Whiteman DC, Stickley M, Watt P, Hughes MC, Davis MB, Green AC. Anatomic site, sun exposure, and risk of cutaneous melanoma. J Clin Oncol. 2006;24(19):3172-3177. [pmid: 16809740].
56 Durbec F, Martin L, Derancourt C, Grange F. Melanoma of the hand and foot: epidemiological, prognostic and genetic features. A systematic review. Br J Dermatol. 2012;166(4):727-739. [pmid: 22175696].
57 Furney SJ, Turajlic S, Fenwick K, et al. Genomic characterisation of acral melanoma cell lines. Pigment Cell Melanoma Res. 2012;25(4):488-492. [pmid: 22578220].
58 Richards TB, Johnson CJ, Tatalovich Z, et al. Association between cutaneous melanoma incidence rates among white U.S. residents and county-level estimates of solar ultraviolet exposure. J Am Acad Dermatol. 2011;65(5 suppl 1):S50.e51-S50.e59. [pmid: 22018067].
59 United States Cancer Statistics: 1999–2010 Mortality. WONDER Online Database. Atlanta, GA. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services. http://wonder.cdc.gov/CancerMort-v2010.html. January 22, 2014.
60 Chapman PB, Hauschild A, Robert C, et al. Improved survival with vemurafenib in melanoma with BRAF V600E mutation. N Engl J Med. 2011;364(26):2507-2516. [pmid: 21639808].
61 Robert C, Thomas L, Bondarenko I, et al. Ipilimumab plus dacarbazine for previously untreated metastatic melanoma. N Engl J Med. 2011;364(26):2517-2526. [pmid: 21639810].
62 Walkington LA, Lorigan P, Danson SJ. Advances in the treatment of late stage melanoma. BMJ. 2013;346:f1265. [pmid: 23460638].
63 Buster KJ, You Z, Fouad M, Elmets C. Skin cancer risk perceptions: a comparison across ethnicity, age, education, gender, and income. J Am Acad Dermatol. 2012;66(5):771-779. [pmid: 21875760].
64 Battie C, Gohara M, Verschoore M, Roberts W. Skin cancer in skin of color: an update on current facts, trends, and misconceptions. J Drugs Dermatol. 2013;12(2):194-198. [pmid: 23377393].
65 Poggi L, Kolesar JM. Vismodegib for the treatment of basal cell skin cancer. Am J Health Syst Pharm. 2013;70(12):1033-1038. [pmid: 23719880].
66 Lin NU. Targeted therapies in brain metastases. Curr Treat Options Neurol. 2014;16(1):276. [pmid: 24353011].
67 Beale S, Dickson R, Bagust A, et al. Vemurafenib for the treatment of locally advanced or metastatic BRAF v600 mutation-positive malignant melanoma: a nice single technology appraisal. Pharmacoeconomics. 2013;31(12):1121-1129. [pmid: 24114739].
68 Bickers DR, Lim HW, Margolis D, et al. The burden of skin diseases, 2004: a joint project of the American Academy of Dermatology Association and the Society for Investigative Dermatology. J Am Acad Dermatol. 2006;55(3):490-500. [pmid: 16908356].
69 Guy GP, Ekwueme DU. Years of potential life lost and indirect costs of melanoma and non-melanoma skin cancer: a systematic review of the literature. Pharmacoeconomics. 2011;29(10):863-874. [pmid: 21846158].
70 Ekwueme DU, Guy GP, Li C, Rim SH, Parelkar P, Chen SC. The health burden and economic costs of cutaneous melanoma mortality by race/ethnicity-United States, 2000 to 2006. J Am Acad Dermatol. 2011;65(5 suppl 1):S133-S143. [pmid: 22018062].
71 Fitzpatrick TB. The validity and practicality of sun-reactive skin types I through VI. Arch Dermatol. 1988;124(6):869-871. [pmid: 3377516].
72 Pichon LC, Landrine H, Corral I, Hao Y, Mayer JA, Hoerster KD. Measuring skin cancer risk in African Americans: is the Fitzpatrick Skin Type Classification Scale culturally sensitive?. Ethn Dis. 2010;20(2):174-179. [pmid: 20503899].
73 Andreassi L, Simoni S, Fiorini P, Fimiani M. Phenotypic characters related to skin type and minimal erythemal dose. Photodermatol. 1987;4(1):43-46. [pmid: 3615247].
74 Beer J, Cesarini J, Cestari T, Diffey B, Miller S, van der Leun J. Sensitivity of human skin to ultraviolet radiation, expressed as Minimal Erythema Dose (MED). Commission Internationale de L'Eclairage (CIE). 2014. http://www.cie.co.at/index.php?i_ca_id=936. April 17, 2014.
75 Tishkoff SA, Reed FA, Friedlaender FR, et al. The genetic structure and history of Africans and African Americans. Science. 2009;324(5930):1035-1044. [pmid: 19407144].
76 Witherspoon DJ, Wooding S, Rogers AR, et al. Genetic similarities within and between human populations. Genetics. 2007;176(1):351-359. [pmid: 17339205].
77 Rouhani P, Pinheiro PS, Sherman R, et al. Increasing rates of melanoma among nonwhites in Florida compared with the United States. Arch Dermatol. 2010;146(7):741-746. [pmid: 20644034].
78 Hu S, Parmet Y, Allen G, et al. Disparity in melanoma: a trend analysis of melanoma incidence and stage at diagnosis among whites, Hispanics, and blacks in Florida. Arch Dermatol. 2009;145(12):1369-1374. [pmid: 20026844].
79 Rouhani P, Hu S, Kirsner RS. Melanoma in Hispanic and black Americans. Cancer Control. 2008;15(3):248-253. [pmid: 18596677].
80 Hall HI, Rogers JD. Sun protection behaviors among African Americans. Ethn Dis. 1999;9(1):126-131. [pmid: 10355481].
81 Coups EJ, Stapleton JL, Hudson SV, et al. Skin cancer surveillance behaviors among U.S. Hispanic adults. J Am Acad Dermatol. 2013;68(4):576-584. [pmid: 23182066].
82 Lucas RM, Ponsonby AL. Ultraviolet radiation and health: friend and foe. Med J Aust. 2002;177(11-12):594-598. [pmid: 12463975].
83 Schein OD, Vicencio C, Muñoz B, et al. Ocular and dermatologic health effects of ultraviolet radiation exposure from the ozone hole in southern Chile. Am J Public Health. 1995;85(4):546-550. [pmid: 7702120].
84 Anderson JG, Wilmouth DM, Smith JB, Sayres DS. UV dosage levels in summer: increased risk of ozone loss from convectively injected water vapor. Science. 2012;337(6096):835-839. [pmid: 22837384].
85 Rivas M, Rojas E, Calaf GM. Prediction of skin cancer occurrence by ultraviolet solar index. Oncol Lett. 2012;3(4):893-896. [pmid: 22741013].
86 Lucas RM, McMichael AJ, Armstrong BK, Smith WT. Estimating the global disease burden due to ultraviolet radiation exposure. Int J Epidemiol. 2008;37(3):654-667. [pmid: 18276627].
87 Dennis LK, Vanbeek MJ, Beane Freeman LE, Smith BJ, Dawson DV, Coughlin JA. Sunburns and risk of cutaneous melanoma: does age matter? A comprehensive meta-analysis. Ann Epidemiol. 2008;18(8):614-627. [pmid: 18652979].
88 Levine H, Afek A, Shamiss A, et al. Country of origin, age at migration and risk of cutaneous melanoma: a migrant cohort study of 1,100,000 Israeli men. Int J Cancer. 2013;133(2):486-494. [pmid: 23319364].
89 Gandini S, Sera F, Cattaruzza MS, et al. Meta-analysis of risk factors for cutaneous melanoma: II. sun exposure. Eur J Cancer. 2005;41(1):45-60. [pmid: 15617990].
90 Walter SD, King WD, Marrett LD. Association of cutaneous malignant melanoma with intermittent exposure to ultraviolet radiation: results of a case-control study in Ontario, Canada. Int J Epidemiol. 1999;28(3):418-427. [pmid: 10405843].
91 Leiter U, Garbe C. Epidemiology of melanoma and non-melanoma skin cancer—the role of sunlight. Reichrath J, editor. Sunlight, Vitamin D and Skin Cancer. New York, NY. Springer. 2008;624:89-103.
92 Rigel DS. Cutaneous ultraviolet exposure and its relationship to the development of skin cancer. J Am Acad Dermatol. 2008;58(5 suppl 2):S129-S132. [pmid: 18410798].
93 Grodstein F, Speizer FE, Hunter DJ. A prospective study of incident squamous cell carcinoma of the skin in the Nurses' Health Study. J Natl Cancer Inst. 1995;87(14):1061-1066. [pmid: 7616597].
94 White E, Kirkpatrick CS, Lee JA. Case-control study of malignant melanoma in Washington state. I. Constitutional factors and sun exposure. Am J Epidemiol. 1994;139(9):857-868. [pmid: 8166136].
95 Kaskel P, Sander S, Kron M, Kind P, Peter RU, Krahn G. Outdoor activities in childhood: a protective factor for cutaneous melanoma? Results of a case-control study in 271 matched pairs. Br J Dermatol. 2001;145(4):602-609. [pmid: 11703287].
96 Singh S, Ajani UA, Johnson CJ, et al. Association of cutaneous malignant melanoma incidence with area-based socioeconomic indicators in the United States. J Am Acad Dermatol. 2011;65(5 suppl 1):S58-S68. [pmid: 22018068].
97 Hu S, Sherman R, Arheart K, Kirsner RS. Predictors of neighborhood risk for late-stage melanoma: addressing disparities through spatial analysis and area-based measures. J Invest Dermatol. 2014;134(4):937-945. [pmid: 24335896].
98 Wang SQ, Setlow R, Berwick M, et al. Ultraviolet A and melanoma: a review. J Am Acad Dermatol. 2001;44(5):837-846. [pmid: 11312434].
99 Green AC, Williams GM, Logan V, Strutton GM. Reduced melanoma after regular sunscreen use: randomized trial follow-up. J Clin Oncol. 2011;29(3):257-263. [pmid: 21135266].
100 Macbeth AE, Grindlay DJ, Williams HC. What's new in skin cancer? An analysis of guidelines and systematic reviews published in 2008-2009. Clin Exp Dermatol. 2011;36(5):453-458. [pmid: 21671988].
101 Gallagher RP, Hill GB, Bajdik CD, et al. Sunlight exposure, pigmentation factors, and risk of nonmelanocytic skin cancer. II. Squamous cell carcinoma. Arch Dermatol. 1995;131(2):164-169. [pmid: 7857112].
102 Gallagher RP, Hill GB, Bajdik CD, et al. Sunlight exposure, pigmentary factors, and risk of nonmelanocytic skin cancer. I. Basal cell carcinoma. Arch Dermatol. 1995;131(2):157-163. [pmid: 7857111].
103 Chang YM, Barrett JH, Bishop DT, et al. Sun exposure and melanoma risk at different latitudes: a pooled analysis of 5,700 cases and 7,216 controls. Int J Epidemiol. 2009;38(3):814-830. [pmid: 19359257].
104 Petersen B, Thieden E, Philipsen PA, Heydenreich J, Wulf HC, Young AR. Determinants of personal ultraviolet-radiation exposure doses on a sun holiday. Br J Dermatol. 2013;168(5):1073-1079. [pmid: 23301517].
105 Thieden E, Philipsen PA, Heydenreich J, Wulf HC. UV radiation exposure related to age, sex, occupation, and sun behavior based on time-stamped personal dosimeter readings. Arch Dermatol. 2004;140(2):197-203. [pmid: 14967793].
106 Parisi AV, Meldrum LR, Kimlin MG, Wong JC, Aitken J, Mainstone JS. Evaluation of differences in ultraviolet exposure during weekend and weekday activities. Phys Med Biol. 2000;45(8):2253-2262. [pmid: 10958193].
107 Almutawa F, Vandal R, Wang SQ, Lim HW. Current status of photoprotection by window glass, automobile glass, window films, and sunglasses. Photodermatol Photoimmunol Photomed. 2013;29(2):65-72. [pmid: 23458389].
108 Mac-Mary S, Sainthillier JM, Jeudy A, et al. Assessment of cumulative exposure to UVA through the study of asymmetrical facial skin aging. Clin Interv Aging. 2010;5:277-284. [pmid: 20924436].
109 Gallagher RP, Elwood JM, Yang CP. Is chronic sunlight exposure important in accounting for increases in melanoma incidence?. Int J Cancer. 1989;44(5):813-815. [pmid: 2583861].
110 Garland FC, White MR, Garland CF, Shaw E, Gorham ED. Occupational sunlight exposure and melanoma in the U.S. Navy. Arch Environ Health. 1990;45(5):261-267. [pmid: 2256710].
111 Pukkala E, Martinsen JI, Lynge E, et al. Occupation and cancer - follow-up of 15 million people in five Nordic countries. Acta Oncol. 2009;48(5):646-790. [pmid: 19925375].
112 Edwards J. Tanning salons in the U.S. IBISWorld Industry Report 81219c. August. 2013.
113 International Agency for Research on Cancer, World Health Organization. Exposure to Artificial UV Radiation and Skin Cancer. Lyon, France. International Agency for Research on Cancer. 2006. http://www.iarc.fr/en/publications/pdfs-online/wrk/wrk1/ArtificialUVRad&SkinCancer.pdf. July 10, 2013.
114 International Agency for Research on Cancer Working Group on Artificial Ultraviolet (UV) Light and Skin Cancer. The association of use of sunbeds with cutaneous malignant melanoma and other skin cancers: a systematic review. Int J Cancer. 2006;120(5):1116-1122.
115 Ferrucci LM, Cartmel B, Molinaro AM, Leffell DJ, Bale AE, Mayne ST. Indoor tanning and risk of early-onset basal cell carcinoma. J Am Acad Dermatol. 2012;67(4):552-562. [pmid: 22153793].
116 Lazovich D, Vogel RI, Berwick M, Weinstock MA, Anderson KE, Warshaw EM. Indoor tanning and risk of melanoma: a case-control study in a highly exposed population. Cancer Epidemiol Biomarkers Prev. 2010;19(6):1557-1568. [pmid: 20507845].
117 Gandini S, Stanganelli I, Magi S, et al. Melanoma attributable to sunbed use and tan seeking behaviours: an Italian survey. Eur J Dermatol. 2014;24(1):35-40. [pmid: 24334101].
118 Boniol M, Autier P, Boyle P, Gandini S. Cutaneous melanoma attributable to sunbed use: systematic review and meta-analysis. BMJ. 2012;345:e4757. [pmid: 22833605].
119 Boniol M, Autier P, Boyle P, Gandini S. Correction: Cutaneous melanoma attributable to sunbed use: systematic review and meta-analysis. BMJ. 2012;345:e8503.
120 Wehner MR, Shive ML, Chren MM, Han J, Qureshi AA, Linos E. Indoor tanning and non-melanoma skin cancer: systematic review and meta-analysis. BMJ. 2012;345:e5909. [pmid: 23033409].
121 Colantonio S, Bracken MB, Beecker J. The association of indoor tanning and melanoma in adults: systematic review and meta-analysis. J Am Acad Dermatol. 2014;70(5):847-857.e018. [pmid: 24629998].
122 Veierod MB, Couto E, Lund E, Adami HO, Weiderpass E. Host characteristics, sun exposure, indoor tanning and risk of squamous cell carcinoma of the skin. Int J Cancer. 2014;135(2):413-422. [pmid: 24408678].
123 Zhang M, Qureshi AA, Geller AC, Frazier L, Hunter DJ, Han J. Use of tanning beds and incidence of skin cancer. J Clin Oncol. 2012;30(14):1588-1593. [pmid: 22370316].
124 Wehner MR, Chren M, Nameth D, et al. International prevalence of indoor tanning: a systematic review and meta-analysis. JAMA Dermatol. 2014;150(4):390-400. [pmid: 24477278].
125 Cust AE, Armstrong BK, Goumas C, et al. Sunbed use during adolescence and early adulthood is associated with increased risk of early-onset melanoma. Int J Cancer. 2011;128(10):2425-2435. [pmid: 20669232].
126 Karagas MR, Zens MS, Li Z, et al. Early-onset basal cell carcinoma and indoor tanning: a population-based study. Pediatrics. 2014.
127 Grant WB. Critique of the International Agency for Research on Cancer's meta-analyses of the association of sunbed use with risk of cutaneous malignant melanoma. Dermatoendocrinol. 2009;1(6):294-299. [pmid: 21572874].
128 Vogel RI, Ahmed RL, Nelson H, Berwick M, Weinstock M, Lazovich D. Exposure to indoor tanning without burning and melanoma risk by sunburn history. J Natl Cancer Inst. 2014;106(6).
129 Nielsen K, Masback A, Olsson H, Ingvar C. A prospective, population-based study of 40,000 women regarding host factors, UV exposure and sunbed use in relation to risk and anatomic site of cutaneous melanoma. Int J Cancer. 2012;131(3):706-715. [pmid: 21898390].
130 Fears TR, Sagebiel RW, Halpern A, et al. Sunbeds and sunlamps: who used them and their risk for melanoma. Pigment Cell Melanoma Res. 2011;24(3):574-581. [pmid: 21362155].
131 Veierod MB, Adami HO, Lund E, Armstrong BK, Weiderpass E. Sun and solarium exposure and melanoma risk: effects of age, pigmentary characteristics, and nevi. Cancer Epidemiol Biomarkers Prev. 2010;19(1):111-120. [pmid: 20056629].
132 Centers for Disease Control and Prevention, Kann L, Kinchen S, et al. Youth risk behavior surveillance — United States, 2013. MMWR Surveill Summ. 2014;63(SS-04):1-168. [pmid: 24918634].
133 Centers for Disease Control and Prevention. Use of indoor tanning devices by adults — United States, 2010. MMWR Morb Mortal Wkly Rep. 2012;61(18):323-326. [pmid: 22572978].
134 Guy GP, Berkowitz Z, Watson M, Holman DM, Richardson LC. Indoor tanning among young non-Hispanic white females. JAMA Intern Med. 2013;173(20):1920-1922. [pmid: 23959651].
135 Gerber B, Mathys P, Moser M, Bressoud D, Braun-Fahrlander C. Ultraviolet emission spectra of sunbeds. Photochem Photobiol. 2002;76(6):664-668. [pmid: 12511047].
136 Hornung RL, Magee KH, Lee WJ, Hansen LA, Hsieh YC. Tanning facility use: are we exceeding Food and Drug Administration limits?. J Am Acad Dermatol. 2003;49(4):655-661. [pmid: 14512912].
137 Tierney P, Ferguson J, Ibbotson S, Dawe R, Eadie E, Moseley H. Nine out of 10 sunbeds in England emit ultraviolet radiation levels that exceed current safety limits. Br J Dermatol. 2013;168(3):602-608. [pmid: 23330641].
138 Miller SA, Hamilton SL, Wester UG, Cyr WH. An analysis of UVA emissions from sunlamps and the potential importance for melanoma. Photochem Photobiol. 1998;68(1):63-70. [pmid: 9679452].
139 National Electronic Injury Surveillance System, All Injury Program. National estimates for tanning bed/booth-related injuries, 2003–2012. Analyzed by National Center for Injury Prevention and Control and National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention. Unpublished data, analyzed 014.
140 Hickle A, Forster J, Lazovich D, et al. Sanitarians' work with indoor-tanning businesses: findings from interviews in two major metropolitan areas. J Environ Health. 2005;67(8):30-36. 54. [pmid: 15856662].
141 Russak JE, Rigel DS. Tanning bed hygiene: microbes found on tanning beds present a potential health risk. J Am Acad Dermatol. 2010;62(1):155-157. [pmid: 20082899].
142 World Health Organization. Ultraviolet radiation and the INTERSUN programme: the known health effects of UV. World Health Organization website. http://www.who.int/uv/faq/uvhealtfac/en/index1.html. December 3, 2013.
143 Quatresooz P, Henry F, Paquet P, Pierard GE. Photoaging under recreational sunbeds. Skin Res Technol. 2011;17(3):309-313. [pmid: 21332806].
144 Borradale D, Isenring E, Hacker E, Kimlin MG. Exposure to solar ultraviolet radiation is associated with a decreased folate status in women of childbearing age. J Photochem Photobiol B. 2014;131(5):90-95. [pmid: 24509071].
145 Lucas RM. An epidemiological perspective of ultraviolet exposure—public health concerns. Eye Contact Lens. 2011;37(4):168-175. [pmid: 21670693].
146 Skin Cancer Foundation. How sunlight damages the eyes. Skin Cancer Foundation website. http://www.skincancer.org/prevention/sun-protection/for-your-eyes/how-sunlight-damages-the-eyes. January 27, 2014.
147 U.S. Environmental Protection Agency, Office of Air and Radiation, SunWise Program. Prevent eye damage: protect yourself from UV radiation. U.S. Environmental Protection Agency website. http://www.epa.gov/sunwise/doc/eyedamage.pdf. January 27, 2014.
148 Freedman DM. Commentary: the complexities of minimizing risks due to UV exposures. Int J Epidemiol. 2008;37(3):667-668. [pmid: 18453633].
149 Ness AR, Frankel SJ, Gunnell DJ, Smith GD. Are we really dying for a tan?. BMJ. 1999;319(7202):114-116. [pmid: 10398641].
150 Woo DK, Eide MJ. Tanning beds, skin cancer, and vitamin D: an examination of the scientific evidence and public health implications. Dermatol Ther. 2010;23(1):61-71. [pmid: 20136909].
151 Institute of Medicine. Dietary Reference Intakes for Calcium and Vitamin D. Washington, DC. Committee to Review Dietary Reference Intakes for Vitamin D and Calcium, Food and Nutrition Board. 2010. http://www.iom.edu/Reports/2010/Dietary-Reference-Intakes-for-calcium-and-vitamin-D.aspx. July 9, 2013.
152 International Agency for Research on Cancer, World Health Organization. Vitamin D and Cancer. Working Group Reports. Lyon, France. International Agency for Research on Cancer. 2008;5. http://www.iarc.fr/en/publications/pdfs-online/wrk/wrk5/Report_VitD.pdf. July 9, 2013.
153 United Nations Environment Programme, International Commission on Non-Ionizing Radiation Protection, World Health Organization. Ultraviolet Radiation: an Authoritative Scientific Review of Environmental and Health Effects of UV, with Reference to Global Ozone Layer Depletion. Geneva, Switzerland. World Health Organization. 1994.
154 Feelisch M, Kolb-Bachofen V, Liu D, et al. Is sunlight good for our heart?. Eur Heart J. 2010;31(9):1041-1045. [pmid: 20215123].
155 Oplander C, Volkmar CM, Paunel-Gorgulu A, et al. Whole body UVA irradiation lowers systemic blood pressure by release of nitric oxide from intracutaneous photolabile nitric oxide derivates. Circ Res. 2009;105(10):1031-1040. [pmid: 19797169].
156 Centers for Disease Control and Prevention. Second National Report on Biochemical Indicators of Diet and Nutrition in the U.S. Population. Atlanta, GA. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services. 2012.
157 Cranney A, Horsley T, O'Donnell S, et al. Effectiveness and safety of vitamin D in relation to bone health. Evid Rep Technol Assess. 2007;(158):1-235.
158 van der Rhee H, Coebergh JW, de Vries E. Is prevention of cancer by sun exposure more than just the effect of vitamin D? A systematic review of epidemiological studies. Eur J Cancer. 2013;49(6):1422-1436. [pmid: 23237739].
159 Chowdhury R, Kunutsor S, Vitezova A, et al. Vitamin D and risk of cause specific death: systematic review and meta-analysis of observational cohort and randomised intervention studies. BMJ. 2014;348:g1903. [pmid: 24690623].
160 Theodoratou E, Tzoulaki I, Zgaga L, Ioannidis JPA. Vitamin D and multiple health outcomes: umbrella review of systematic reviews and meta-analyses of observational studies and randomised trials. BMJ. 2014;348:g2035. [pmid: 24690624].
161 Brondum-Jacobsen P, Nordestgaard BG, Nielsen SF, Benn M. Skin cancer as a marker of sun exposure associates with myocardial infarction, hip fracture and death from any cause. Int J Epidemiol. 2013;42(5):1486-1496. [pmid: 24038635].
162 Rosen CJ, Adams JS, Bikle DD, et al. The nonskeletal effects of vitamin D: an Endocrine Society scientific statement. Endocr Rev. 2012;33(3):456-492. [pmid: 22596255].
163 Boscoe FP, Schymura MJ. Solar ultraviolet-B exposure and cancer incidence and mortality in the United States, 1993-2002. BMC Cancer. 2006;6:264. [pmid: 17096841].
164 Holick MF. Vitamin D, sunlight and cancer connection. Anticancer Agents Med Chem. 2013;13(1):70-82. [pmid: 23094923].
165 Grant WB, Mohr SB. Ecological studies of ultraviolet B, vitamin D and cancer since 2000. Ann Epidemiol. 2009;19(7):446-454. [pmid: 19269856].
166 Autier P, Boniol M, Pizot C, Mullie P. Vitamin D status and ill health: a systematic review. Lancet Diabetes Endocrinol. 2014;2(1):76-89. [pmid: 24622671].
167 Lin SW, Wheeler DC, Park Y, et al. Prospective study of ultraviolet radiation exposure and mortality risk in the United States. Am J Epidemiol. 2013;178(4):521-533. [pmid: 23863757].
168 Song EJ, Gordon-Thomson C, Cole L, et al. 1alpha,25-dihydroxyvitamin D3 reduces several types of UV-induced DNA damage and contributes to photoprotection. J Steroid Biochem Mol Biol. 2013;136:131-138. [pmid: 23165145].
169 Chung M, Balk EM, Brendel M, et al. Vitamin D and Calcium: A Systematic Review of Health Outcomes. Rockville, MD. Agency for Healthcare Research and Quality, U.S. Dept of Health and Human Services. 2009.
170 Bolland MJ, Grey A, Gamble GD, Reid IR. The effect of vitamin D supplementation on skeletal, vascular, or cancer outcomes: a trial sequential meta-analysis. Lancet Diabetes Endocrinol. 2014;2(4):307-320. [pmid: 24703049].
171 Welsh P, Sattar N. Vitamin D and chronic disease prevention. BMJ. 2014;348:g2280. [pmid: 24690627].
172 Looker AC, Johnson CL, Lacher DA, Pfeiffer CM, Schleicher RL, Sempos CT. Vitamin D status: United States, 2001-2006. NCHS Data Brief. 2011;59. http://www.cdc.gov/nchs/data/databriefs/db59.htm. December 6, 2013.
173 National Institutes of Health, Office of Dietary Supplements. Dietary supplement fact sheet: vitamin D. National Institutes of Health website. http://ods.od.nih.gov/factsheets/VitaminD-HealthProfessional/. July 15, 2013.
174 Powe CE, Evans MK, Wenger J, et al. Vitamin D–binding protein and vitamin D status of black Americans and white Americans. N Engl J Med. 2013;369(21):1991-2000. [pmid: 24256378].
175 Aloia JF. African Americans, 25-hydroxyvitamin D, and osteoporosis: a paradox. Am J Clin Nutr. 2008;88(2):545S-550S. [pmid: 18689399].
176 Centers for Disease Control and Prevention. Vitamin D supplementation. Centers for Disease Control and Prevention website. http://www.cdc.gov/breastfeeding/recommendations/vitamin_D.htm. December 11, 2013.
177 Wagner CL, Greer FR, American Academy of Pediatrics Section on Breastfeeding, American Academy of Pediatrics Committee on Nutrition. Prevention of rickets and vitamin D deficiency in infants, children, and adolescents. Pediatrics. 2008;122(5):1142-1152. [pmid: 18977996].
178 Cancer Council Victoria. Vitamin D—getting the balance right. Cancer Council Victoria website. http://www.cancervic.org.au/about/publications/reports-and-submissions/ciss-hp-enews/vitamin-d-the-right-amount.html. December 6, 2013.
179 Chen TC, Chimeh F, Lu Z, et al. Factors that influence the cutaneous synthesis and dietary sources of vitamin D. Arch Biochem Biophys. 2007;460(2):213-217. [pmid: 17254541].
180 Lin JY, Fisher DE. Melanocyte biology and skin pigmentation. Nature. 2007;445(7130):843. [pmid: 17314970].
181 Holick MF. Sunlight “D”ilemma: risk of skin cancer or bone disease and muscle weakness. Lancet. 2001;357(9249):4-6. [pmid: 11197362].
182 Brannon PM, Yetley EA, Bailey RL, Picciano MF. Overview of the conference “Vitamin D and Health in the 21st Century: an Update”. Am J Clin Nutr. 2008;88(2):483S-490S. [pmid: 18689388].
183 Holick MF. The cutaneous photosynthesis of previtamin D3: a unique photoendocrine system. J Invest Dermatol. 1981;77(1):51-58. [pmid: 6265564].
184 Wolpowitz D, Gilchrest BA. The vitamin D questions: how much do you need and how should you get it?. J Am Acad Dermatol. 2006;54(2):301-317. [pmid: 16443061].
185 Olds WJ, McKinley AR, Moore MR, Kimlin MG. In vitro model of vitamin D3 (cholecalciferol) synthesis by UV radiation: dose-response relationships. J Photochem Photobiol B. 2008;93(2):88-93. [pmid: 18755599].
186 Nichols EK, Khatib IM, Aburto NJ, et al. Vitamin D status and determinants of deficiency among non-pregnant Jordanian women of reproductive age. Eur J Clin Nutr. 2012;66(6):751-756. [pmid: 22415337].
187 U.S. Food and Drug Administration, U.S. Department of Health and Human Services. Sunscreen drug products for over-the-counter human use. Code of Federal Regulations Title 21, Volume 76, Number 117, Parts 201, 310, and 352. (June 17, 2011). Fed Regist. 2011. http://www.gpo.gov/fdsys/pkg/FR-2011-06-17/html/2011-14766.htm.
188 Heaney RP, Armas LA, French C. All-source basal vitamin D inputs are greater than previously thought and cutaneous inputs are smaller. J Nutr. 2013;143(5):571-575. [pmid: 23514768].
189 U.S. Department of Agriculture. USDA National Nutrient Database for Standard Reference. Nutrient Data Lab website. http://ndb.nal.usda.gov/. January 21, 2014.
190 Green C, Diffey BL, Hawk JL. Ultraviolet radiation in the treatment of skin disease. Phys Med Biol. 1992;37(1):1-20. [pmid: 1741417].
191 Menter A, Korman NJ, Elmets CA, et al. Guidelines of care for the management of psoriasis and psoriatic arthritis. Section 6. Guidelines of care for the treatment of psoriasis and psoriatic arthritis: case-based presentations and evidence-based conclusions. J Am Acad Dermatol. 2011;65(1):137-174. [pmid: 21306785].
192 Misra M, Pacaud D, Petryk A, et al. Vitamin D deficiency in children and its management: review of current knowledge and recommendations. Pediatrics. 2008;122(2):398-417. [pmid: 18676559].
193 Ring J, Alomar A, Bieber T, et al. Guidelines for treatment of atopic eczema (atopic dermatitis) part I. J Eur Acad Dermatol Venereol. 2012;26(8):1045-1060. [pmid: 22805051].
194 Ring J, Alomar A, Bieber T, et al. Guidelines for treatment of atopic eczema (atopic dermatitis) part II. J Eur Acad Dermatol Venereol. 2012;26(9):1176-1193. [pmid: 22813359].
195 Menter A, Korman NJ, Elmets CA, et al. Guidelines of care for the management of psoriasis and psoriatic arthritis. Section 5. Guidelines of care for the treatment of psoriasis with phototherapy and photochemotherapy. J Am Acad Dermatol. 2010;62(1):114-135. [pmid: 19811850].
196 Brehler R, Hildebrand A, Luger TA. Recent developments in the treatment of atopic eczema. J Am Acad Dermatol. 1997;36(6 pt 1):983-994. [pmid: 9204066].
197 McCurdy LE, Winterbottom KE, Mehta SS, Roberts JR. Using nature and outdoor activity to improve children's health. Curr Probl Pediatr Adolesc Health Care. 2010;40(5):102-117. [pmid: 20381783].
198 Bowler DE, Buyung-Ali LM, Knight TM, Pullin AS. A systematic review of evidence for the added benefits to health of exposure to natural environments. BMC Public Health. 2010;10:456. [pmid: 20684754].
199 Sallis JF, Prochaska JJ, Taylor WC. A review of correlates of physical activity of children and adolescents. Med Sci Sports Exerc. 2000;32(5):963-975. [pmid: 10795788].
200 Sugiyama T, Leslie E, Giles-Corti B, Owen N. Associations of neighbourhood greenness with physical and mental health: do walking, social coherence and local social interaction explain the relationships?. J Epidemiol Community Health. 2008;62(5).
201 Astell-Burt T, Feng X, Kolt GS. Green space is associated with walking and moderate-to-vigorous physical activity (MVPA) in middle-to-older-aged adults: findings from 203,883 Australians in the 45 and Up Study. Br J Sports Med. 2014;48(5):404-406. [pmid: 23632744].
202 Timperio A, Giles-Corti B, Crawford D, et al. Features of public open spaces and physical activity among children: findings from the CLAN study. Prev Med. 2008;47(5):514-518. [pmid: 18718847].
203 Boldemann C, Blennow M, Dal H, et al. Impact of preschool environment upon children's physical activity and sun exposure. Prev Med. 2006;42(4):301-308. [pmid: 16448688].
204 Colabianchi N, Maslow AL, Swayampakala K. Features and amenities of school playgrounds: a direct observation study of utilization and physical activity levels outside of school time. Int J Behav Nutr Phys Act. 2011;8:32. [pmid: 21492455].
205 Sivamani RK, Crane LA, Dellavalle RP. The benefits and risks of ultraviolet tanning and its alternatives: the role of prudent sun exposure. Dermatol Clin. 2009;27(2):149-154. [pmid: 19254658].
206 Miyamura Y, Coelho SG, Schlenz K, et al. The deceptive nature of UVA tanning versus the modest protective effects of UVB tanning on human skin. Pigment Cell Melanoma Res. 2011;24(1):136-147. [pmid: 20979596].
207 Sallander E, Wester U, Bengtsson E, Wiegleb Edstrom D. Vitamin D levels after UVB radiation: effects by UVA additions in a randomized controlled trial. Photodermatol Photoimmunol Photomed. 2013;29(6):323-329. [pmid: 24118541].
208 Thieden E, Jorgensen HL, Jorgensen NR, Philipsen PA, Wulf HC. Sunbed radiation provokes cutaneous vitamin D synthesis in humans—a randomized controlled trial. Photochem Photobiol. 2008;84(6):1487-1492. [pmid: 18513233].
209 Zhang M, Song F, Hunter DJ, Qureshi AA, Han J. Tanning bed use is not associated with internal cancer risk: evidence from a large cohort study. Cancer Epidemiol Biomarkers Prev. 2013;22(12):2425-2429. [pmid: 24130225].
210 Yang L, Lof M, Veierod MB, Sandin S, Adami HO, Weiderpass E. Ultraviolet exposure and mortality among women in Sweden. Cancer Epidemiol Biomarkers Prev. 2011;20(4):683-690. [pmid: 21297041].
211 Vannini P, McCright AM. To die for: the semiotic seductive power of the tanned body. Symbolic Interaction. 2004;27(3):309-332.
212 Dennis LK, Lowe JB. Does artificial UV use prior to spring break protect students from sunburns during spring break?. Photodermatol Photoimmunol Photomed. 2013;29(3):140-148. [pmid: 23651274].
213 Pedeux R, Al-Irani N, Marteau C, et al. Thymidine dinucleotides induce s phase cell cycle arrest in addition to increased melanogenesis in human melanocytes. J Invest Dermatol. 1998;111(3):472-477. [pmid: 9740243].
214 Eller MS, Maeda T, Magnoni C, Atwal D, Gilchrest BA. Enhancement of DNA repair in human skin cells by thymidine dinucleotides: evidence for a p53-mediated mammalian SOS response. Proc Natl Acad Sci U S A. 1997;94(23):12627-12632. [pmid: 9356500].
215 Agar N, Young AR. Melanogenesis: a photoprotective response to DNA damage?. Mutat Res. 2005;571(1-2):121-132. [pmid: 15748643].
216 Young AR. Tanning devices—fast track to skin cancer?. Pigment Cell Res. 2004;17(1):2-9. [pmid: 14717839].
217 Sheehan JM, Potten CS, Young AR. Tanning in human skin types II and III offers modest photoprotection against erythema. Photochem Photobiol. 1998;68(4):588-592. [pmid: 9796443].
218 Ruegemer J, Schuetz B, Hermann K, Hein R, Ring J, Abeck D. UV-induced skin changes due to regular use of commercial sunbeds. Photodermatol Photoimmunol Photomed. 2002;18(5):223-227. [pmid: 12390662].
219 Lee TM, Chan CC, Paterson JG, Janzen HL, Blashko CA. Spectral properties of phototherapy for seasonal affective disorder: a meta-analysis. Acta Psychiatr Scand. 1997;96(2):117-121. [pmid: 9272195].
220 Hillhouse J, Stapleton J, Turrisi R. Association of frequent indoor UV tanning with seasonal affective disorder. Arch Dermatol. 2005;141(11):1465. [pmid: 16301398].
221 Hillhouse J, Turrisi R, Stapleton J, Robinson J. Effect of seasonal affective disorder and pathological tanning motives on efficacy of an appearance-focused intervention to prevent skin cancer. Arch Dermatol. 2010;146(5):485-491. [pmid: 20479295].
222 Partonen T, Lonnqvist J. Seasonal affective disorder. Lancet. 1998;352(9137):1369-1374. [pmid: 9802288].
223 Centers for Disease Control and Prevention, Brener ND, Kann L, et al. Methodology of the Youth Risk Behavior Surveillance System — 2013. MMWR Recomm Rep. 2013;62(RR-1):1-20. [pmid: 23446553].
224 Centers for Disease Control and Prevention. National Health Interview Survey. Centers for Disease Control and Prevention website. http://www.cdc.gov/nchs/nhis.htm. April 9, 2013.
225 Eaton DK, Kann L, Kinchen S, et al. Youth risk behavior surveillance — United States, 2011. MMWR Surveill Summ. 2012;61(4):1-162. [pmid: 22673000].
226 Holman DM, Berkowitz Z, Guy GP, Hartman AM, Perna FM. The association between demographic and behavioral characteristics and sunburn among U.S. Adults – National Health Interview Survey, 2010. Prev Med. 2014;63:6-12. [pmid: 24589442].
227 Centers for Disease Control and Prevention. Sunburn and sun protective behaviors among adults aged 18–29 years — United States, 2000–2010. MMWR Morb Mortal Wkly Rep. 2012;61(18):317-322. [pmid: 22572977].
228 Buller DB, Cokkinides V, Hall HI, et al. Prevalence of sunburn, sun protection, and indoor tanning behaviors among Americans: review from national surveys and case studies of 3 states. J Am Acad Dermatol. 2011;65(5 suppl 1):S114-S123. [pmid: 22018060].
229 Robinson JK, Baker MK, Hillhouse JJ. New approaches to melanoma prevention. Dermatol Clin. 2012;30(3):405-412. [pmid: 22800548].
230 Goulart JM, Wang SQ. Knowledge, motivation, and behavior patterns of the general public towards sun protection. Photochem Photobiol Sci. 2010;9(4):432-438. [pmid: 20354635].
231 International Agency for Research on Cancer. IARC Handbook on Cancer Prevention. Volume 5: Sunscreens. Lyon, France. International Agency for Research on Cancer, World Health Organization. 2001.
232 Lazovich D, Choi K, Vogel RI. Time to get serious about skin cancer prevention. Cancer Epidemiol Biomarkers Prev. 2012;21(11):1893-1901. [pmid: 22962407].
233 Kinney JP, Long CS, Geller AC. The ultraviolet index: a useful tool. Dermatol Online J. 2000;6(1).
234 Rosenthal FS, Phoon C, Bakalian AE, Taylor HR. The ocular dose of ultraviolet radiation to outdoor workers. Invest Ophthalmol Vis Sci. 1988;29(4):649-656. [pmid: 3356520].
235 U.S. Food and Drug Administration. Sunburn protection factor (SPF). U.S. Food and Drug Administration website. http://www.fda.gov/aboutfda/centersoffices/officeofmedicalproductsandtobacco/cder/ucm106351.htm. April 30, 2014.
236 van der Pols JC, Williams GM, Pandeya N, Logan V, Green AC. Prolonged prevention of squamous cell carcinoma of the skin by regular sunscreen use. Cancer Epidemiol Biomarkers Prev. 2006;15(12):2546-2548. [pmid: 17132769].
237 Chesnut C, Kim J. Is there truly no benefit with sunscreen use and basal cell carcinoma? A critical review of the literature and the application of new sunscreen labeling rules to real-world sunscreen practices. J Skin Cancer. 2012;2012:480985. [pmid: 22649734].
238 Hughes MC, Williams GM, Baker P, Green AC. Sunscreen and prevention of skin aging: a randomized trial. Ann Intern Med. 2013;158(11):781-790. [pmid: 23732711].
239 Centers for Disease Control and Prevention. Sun safety. Centers for Disease Control and Prevention website. http://www.cdc.gov/cancer/skin/basic_info/sun-safety.htm#sunscreen. March 24, 2014.
240 Diffey BL. When should sunscreen be reapplied?. J Am Acad Dermatol. 2001;45(6):882-885. [pmid: 11712033].
241 Jansen R, Osterwalder U, Wang SQ, Burnett M, Lim HW. Photoprotection: Part II. Sunscreen: development, efficacy, and controversies. J Am Acad Dermatol. 2013;69(6):867.e001-867.e014. [pmid: 24238180].
242 Reimann V, Kramer U, Sugiri D, et al. Sunbed use induces the photoaging-associated mitochondrial common deletion. J Invest Dermatol. 2008;128(5):1294-1297. [pmid: 17989728].
243 Dadlani C, Orlow SJ. Planning for a brighter future: a review of sun protection and barriers to behavioral change in children and adolescents. Dermatol Online J. 2008;14(9):1. [pmid: 19061583].
244 National Cancer Institute, U.S. National Institutes of Health. Health Information National Trends Survey (HINTS). National Cancer Institute website. http://hints.cancer.gov/. January 13, 2014.
245 Roche L, Wu XC, Chen VW, et al. Cutaneous melanoma incidence and survival among black, Asian and Pacific Islander and white populations in the United States. Clin Med Insights Dermatol. 2010;3:15-24.
246 Han PK, Moser RP, Klein WM. Perceived ambiguity about cancer prevention recommendations: associations with cancer-related perceptions and behaviours in a U.S. population survey. Health Expect. 2007;10(4):321-336. [pmid: 17986069].
247 Italia N, Rehfuess EA. Is the global solar UV index an effective instrument for promoting sun protection? A systematic review. Health Educ Res. 2012;27(2):200-213. [pmid: 21730253].
248 Allinson S, Asmuss M, Baldermann C, et al. Validity and use of the UV index: report from the UVI working group, Schloss Hohenkammer, Germany, December 5-7, 2011. Health Phys. 2012;103(3):301-306. [pmid: 22850235].
249 Mahe E, Beauchet A, de Maleissye MF, Saiag P. Are sunscreens luxury products?. J Am Acad Dermatol. 2011;65(3):e73-e79. [pmid: 21742412].
250 Jinna S, Adams BB. Ultraviolet radiation and the athlete: risk, sun safety, and barriers to implementation of protective strategies. Sports Med. 2013;43(7):531-537. [pmid: 23568372].
251 Council on Sports Medicine and Fitness, Council on School Health, Bergeron MF, Devore C, Rice SG, American Academy of Pediatrics. Policy statement-climatic heat stress and exercising children and adolescents. Pediatrics. 2011;128(3):e741-e747. [pmid: 21824876].
252 Abroms L, Jorgensen CM, Southwell BG, Geller AC, Emmons KM. Gender differences in young adults' beliefs about sunscreen use. Health Educ Behav. 2003;30(1):29-43. [pmid: 12564666].
253 Wang SQ, Dusza SW. Assessment of sunscreen knowledge: a pilot survey. Br J Dermatol. 2009;161(suppl 3):28-32. [pmid: 19775354].
254 Carrera C, Puig-Butille JA, Aguilera P, et al. Impact of sunscreens on preventing UVR-induced effects in nevi: in vivo study comparing protection using a physical barrier vs sunscreen. JAMA Dermatol. 2013;149(7):803-813. [pmid: 23699984].
255 Diffey BL, Cheeseman J. Sun protection with hats. Br J Dermatol. 1992;127(1):10-12. [pmid: 1637687].
256 Wickenheiser M, Baker MK, Gaber R, Blatt H, Robinson JK. Sun protection preferences and behaviors among young adult males during maximum ultraviolet radiation exposure activities. Int J Environ Res Public Health. 2013;10(8):3203-3216. [pmid: 23912201].
257 Jardine A, Bright M, Knight L, Perina H, Vardon P, Harper C. Does physical activity increase the risk of unsafe sun exposure?. Health Promot J Austr. 2012;23(1):52-57. [pmid: 22730941].
258 Tran AD, Aalborg J, Asdigian NL, et al. Parents' perceptions of skin cancer threat and children's physical activity. Prev Chronic Dis. 2012;9:e143. [pmid: 22935145].
259 Coups EJ, Phillips LA. A more systematic review of correlates of indoor tanning. J Eur Acad Dermatol Venereol. 2011;25(5):610-616. [pmid: 21349117].
260 Holman DM, Fox KA, Glenn JD, et al. Strategies to reduce indoor tanning: current research gaps and future opportunities for prevention. Am J Prev Med. 2013;44(6):672-681. [pmid: 23683986].
261 Schneider S, Kramer H. Who uses sunbeds? A systematic literature review of risk groups in developed countries. J Eur Acad Dermatol Venereol. 2010;24(6):639-648. [pmid: 20015180].
262 Watson M, Holman DM, Fox KA, et al. Preventing skin cancer through reduction of indoor tanning: current evidence. Am J Prev Med. 2013;44(6):682-689. [pmid: 23683987].
263 Hillhouse J, Turrisi R, Stapleton J, Robinson J. A randomized controlled trial of an appearance-focused intervention to prevent skin cancer. Cancer. 2008;113(11):3257-3266. [pmid: 18937268].
264 Hillhouse JJ, Turrisi R. Examination of the efficacy of an appearance-focused intervention to reduce UV exposure. J Behav Med. 2002;25(4):395-409. [pmid: 12136499].
265 Moyer VA, U.S. Preventive Services Task Force. Behavioral counseling to prevent skin cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;157(1):59-65. [pmid: 22751761].
266 Mahler HI, Kulik JA, Gerrard M, Gibbons FX. Long-term effects of appearance-based interventions on sun protection behaviors. Health Psychol. 2007;26(3):350-360. [pmid: 17500622].
267 Hillhouse J, Turrisi R, Shields AL. Patterns of indoor tanning use: implications for clinical interventions. Arch Dermatol. 2007;143(12):1530-1535. [pmid: 18087003].
268 Levine JA, Sorace M, Spencer J, Siegel DM. The indoor UV tanning industry: a review of skin cancer risk, health benefit claims, and regulation. J Am Acad Dermatol. 2005;53(6):1038-1044. [pmid: 16310065].
269 Cho H, Hall JG, Kosmoski C, Fox RL, Mastin T. Tanning, skin cancer risk, and prevention: a content analysis of eight popular magazines that target female readers, 1997-2006. Health Commun. 2010;25(1):1-10. [pmid: 20228954].
270 Kourosh AS, Harrington CR, Adinoff B. Tanning as a behavioral addiction. Am J Drug Alcohol Abuse. 2010;36(5):284-290. [pmid: 20545604].
271 Shah A, Smith S, Heckman C. Tanning dependence: is tanning an addiction?. Heckman CJ, Manne SL, editors. Shedding Light on Indoor Tanning. New York, NY. Springer. 2012:107-120.
272 Juzeniene A, Moan J. Beneficial effects of UV radiation other than via vitamin D production. Dermatoendocrinol. 2012;4(2):109-117. [pmid: 22928066].
273 Banerjee SC. Fact or wishful thinking? Biased expectations in I think I look better when I'm tanned. Am J Health Behav. 2008;32(3):243-252. [pmid: 18067464].
274 Strahan EJ, Wilson AE, Cressman KE, Buote VM. Comparing to perfection: how cultural norms for appearance affect social comparisons and self-image. Body Image. 2006;3(3):211-227. [pmid: 18089224].
275 Holman DM, Watson M. Correlates of intentional tanning among adolescents in the United States: a systematic review of the literature. J Adolesc Health. 2013;52(5 suppl):S52-S59. [pmid: 23601612].
276 Hunt Y, Auguston E, Rutten L, Moser R. History and culture of tanning in the United States. Heckman CJ, Manne EL, editors. Shedding Light on Indoor Tanning. New York, NY. Springer. 2012:5-30.
277 Lin JS, Eder M, Weinmann S. Behavioral counseling to prevent skin cancer: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2011;154(3):190-201. [pmid: 21282699].
278 U.S. Preventive Services Task Force. Behavioral counseling to prevent skin cancer: U.S. Preventive Services Task Force recommendation statement website. http://www.uspreventiveservicestaskforce.org/uspstf11/skincancouns/skincancounsrs.htm. May 16, 2013.
279 Maxwell KA. Friends: The role of peer influence across adolescent risk behaviors. J Youth Adolesc. 2002;31(4):267-277.
280 U.S. Food and Drug Administration. Color additives. Code of Federal Regulations Title 21 (73). Fed Regist. 2012.
281 Brooks K, Brooks D, Dajani Z, et al. Use of artificial tanning products among young adults. J Am Acad Dermatol. 2006;54(6):1060-1066. [pmid: 16713463].
282 Cokkinides VE, Bandi P, Weinstock MA, Ward E. Use of sunless tanning products among U.S. adolescents aged 11 to 18 years. Arch Dermatol. 2010;146(9):987-992. [pmid: 20855697].
283 Mahoney A, Swetter SM, Biello KB, Resnick EA, Feuerstein I, Geller AC. Attitudes toward indoor tanning among users of sunless tanning products. Arch Dermatol. 2012;148(1):124-126. [pmid: 22250251].
284 Paul CL, Paras L, Harper A, Coppa K. Harm minimization in tan seekers: an exploration of tanning behaviour and the potential for substitutional use of sunless tanning products. J Health Psychol. 2011;16(6):929-937. [pmid: 21441364].
285 Stryker JE, Yaroch AL, Moser RP, Atienza A, Glanz K. Prevalence of sunless tanning product use and related behaviors among adults in the United States: results from a national survey. J Am Acad Dermatol. 2007;56(3):387-390. [pmid: 17097362].
286 Beckmann KR, Kirke BA, McCaul KA, Roder DM. Use of fake tanning lotions in the south Australian population. Med J Aust. 2001;174(2):75-78. [pmid: 11245507].
287 Girgis A, Tzelepis F, Paul CL, Walsh RA, McElduff P, McKenzie J. Australians' use of fake tanning lotions: another piece of the puzzle. Aust N Z J Public Health. 2003;27(5):529-532. [pmid: 14651400].
288 O'Leary RE, Diehl J, Levins PC. Update on tanning: more risks, fewer benefits. J Am Acad Dermatol. 2014;70(30):562-568. [pmid: 24388421].
289 Balk SJ, Council on Environmental Health, Section on Dermatology. Ultraviolet radiation: a hazard to children and adolescents. Pediatrics. 2011;127(3):e791-e817. [pmid: 21357345].
290 American Cancer Society. American Cancer Society guidelines for the early detection of cancer. American Cancer Society website. http://www.cancer.org/healthy/findcancerearly/cancerscreeningguidelines/american-cancer-society-guidelines-for-the-early-detection-of-cancer. September 30, 2013.
291 Geller AC, Zhang Z, Sober AJ, et al. The first 15 years of the American Academy of Dermatology skin cancer screening programs: 1985-1999. J Am Acad Dermatol. 2003;48(1):34-41. [pmid: 12522368].
292 U.S. Preventive Services Task Force. Screening for skin cancer: recommendation statement. U.S. Preventive Services Task Force website. http://www.uspreventiveservicestaskforce.org/uspstf09/skincancer/skincanrs.htm. September 30, 2013.
293 U.S. Preventive Services Task Force. Previous opportunities for public comment. U.S. Preventive Services Task Force website. http://www.uspreventiveservicestaskforce.org/tflistprev.htm. July 22, 2014.
294 Saraiya M, Glanz K, Briss PA, et al. Interventions to prevent skin cancer by reducing exposure to ultraviolet radiation: a systematic review. Am J Prev Med. 2004;27(5):422-466. [pmid: 15556744].
295 Community Preventive Services Task Force. Recommendations to prevent skin cancer by reducing exposure to ultraviolet radiation. Am J Prev Med. 2004;27(5):467-470. [pmid: 15556745].
296 Community Preventive Services Task Force. Cancer prevention & control. The Guide to Community Preventive Services website. http://www.thecommunityguide.org/cancer/index.html. May 16, 2013.
297 World Health Organization. Sun Protection in Schools: an Educational Package to Protect Children from Ultraviolet Radiation. Geneva, Switzerland. World Health Organization. 2003. http://www.who.int/uv/publications/en/sunprotschools.pdf. July 15, 2013.
298 DiClimente RJ, Santelli JS, Crosby RA. Adolescents at risk: a generation in jeopardy. DiClimente RJ, Santelli JS, Crosby RA, editors. Adolescent Health: Understanding and Preventing Risk Behaviors. San Francisco, CA. Jossey-Bass. 2009:3-27.
299 Centers for Disease Control and Prevention. Chapter 8. Safe and healthy school environment. Results from the School Health Policies and Practices Study 2012. Atlanta, GA. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services. 2013. http://www.cdc.gov/healthyyouth/shpps/2012/pdf/shpps-results_2012.pdf. January 9, 2014.
300 Reynolds KD, Buller DB, French SA, Buller MK, Ashley JL. School sun-protection policies: Measure development and assessments in 2 regions of the United States. J Sch Health. 2012;82(11):499-507. [pmid: 23061553].
301 Buller DB, Reynolds KD, Ashley JL, et al. Motivating public school districts to adopt sun protection policies: a randomized controlled trial. Am J Prev Med. 2011;41(3):309-316. [pmid: 21855746].
302 The 188th General Court of the Commonwealth of Massachusetts. http://malegislature.gov/Bills/188/Senate/S279. July 17, 2013.
303 Arizona Department of Health Services. SunWise Skin Cancer Prevention School Program. Arizona Department of Health Services website. http://www.azdhs.gov/phs/sunwise/. July 17, 2013.
304 Townsend JS, Pinkerton B, McKenna SA, et al. Targeting children through school-based education and policy strategies: comprehensive cancer control activities in melanoma prevention. J Am Acad Dermatol. 2011;65(5 suppl 1):S104-S113. [pmid: 22018059].
305 Kann L, Telljohann SK, Wooley SF. Health education: results from the School Health Policies and Programs Study 2006. J Sch Health. 2007;77(8):408-434. [pmid: 17908101].
306 Community Preventive Services Task Force. The Community Guide: what works to promote health. The Guide to Community Preventive Services website. http://www.thecommunityguide.org/index.html. July 9, 2013.
307 Crane LA, Mokrohisky ST, Dellavalle RP, et al. Melanocytic nevus development in Colorado children born in 1998: a longitudinal study. Arch Dermatol. 2009;145(2):148-156. [pmid: 19221259].
308 Centers for Disease Control and Prevention. Shade Planning for America's Schools. Atlanta, GA. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services. 2008. http://www.cdc.gov/cancer/skin/pdf/shade_planning.pdf. January 16, 2014.
309 Community Preventive Services Task Force. Preventing skin cancer: interventions in outdoor occupational settings. The Guide to Community Preventive Services website. http://www.thecommunityguide.org/cancer/skin/education-policy/outdooroccupations.html. December 9, 2013.
310 Janda M, Stoneham M, Youl P, et al. What encourages sun protection among outdoor workers from four industries?. J Occup Health. 2014;56(1):62-72. [pmid: 24270927].
311 Nahar VK, Ford MA, Hallam JS, Bass MA, Vice MA. Sociodemographic and psychological correlates of sun protection behaviors among outdoor workers: a review. J Skin Cancer. 2013;453174.
312 Laborers' Health & Safety Fund of North America. Skin in the game. Laborers' Health & Safety Fund of North America website. http://www.lhsfna.org/index.cfm/lifelines/may-2013/skin-in-the-game/. December 12, 2013.
313 Wallis A, Andersen PA, Buller DB, et al. Adoption of sun safe workplace practices by local governments. J Public Health Manag Pract. 2013.
314 Frieden TR. A framework for public health action: the health impact pyramid. Am J Public Health. 2010;100(4):590-595. [pmid: 20167880].
315 State of California. SB 1632, ch 266. Perata. Pupils: sun protection. “Billy's bill for sun safety”. 2002. http://www.leginfo.ca.gov/pub/01-02/bill/sen/sb_1601-1650/sb_1632_bill_20020826_chaptered.html.
316 New York State Legislature. Use of sunscreen. Article 19: Section 907. http://public.leginfo.state.ny.us/LAWSSEAF.cgi?QUERYTYPE=LAWS+&QUERYDATA=@SLEDN0T1A19+&LIST=SEA2+&BROWSER=EXPLORER+&TOKEN=34261658+&TARGET=VIEW. May 2, 2014.
317 California School Boards Association. Governance & policy services: policy briefs. Sun safety in schools. 2006. http://www.csba.org/GovernanceAndPolicyResources/DistrictPolicyServices/∼/media/CSBA/Files/GovernanceResources/PolicyNews_Briefs/StudentHealth/SunSafety/2006_07_PolicyBrief_SunSafetyInschools.ashx. March 24, 2014.
318 California School Boards Association. CSBA sample board policy: students: sun safety. BP 5141.7(a-d). http://www.csba.org/Services/Services/PolicyServices/∼/media/Files/Services/PolicyServices/SamplePolicies/SunSafetyBP.ashx. March 21, 2014.
319 State of California. AB 663, Vargas. Worker's compensation: lifeguards. 2001. http://www.leginfo.ca.gov/pub/01-02/bill/asm/ab_0651-0700/ab_663_bill_20011013_chaptered.html. February 2, 2014.
320 State of California. SCR 25, Speier. Resolution chapter 105. Employer safety practices. 2005. http://www.leginfo.ca.gov/pub/05-06/bill/sen/sb_0001-0050/scr_25_bill_20050906_chaptered.html. February 3, 2014.
321 State of New York. New York education law 804. Title 1, Article 17. http://public.leginfo.state.ny.us/LAWSSEAF.cgi?QUERYTYPE=LAWS+&QUERYDATA=$$EDN804$$@TXEDN0804+&LIST=SEA7+&BROWSER=EXPLORER+&TOKEN=51461778+&TARGET=VIEW. September 9, 2013.
322 Kentucky General Assembly. 158.301 Legislative findings on skin cancer risks: schools encouraged to educate students on risks of exposure to ultraviolet rays. 2006. http://www.lrc.ky.gov/Statutes/statute.aspx?id=3496. September 9, 2013.
323 State of New York. New York Labor Law Article 7, 218-A. http://public.leginfo.state.ny.us/LAWSSEAF.cgi?QUERYTYPE=LAWS+&QUERYDATA=$$LAB218-A$$@TXLAB0218-A+&LIST=SEA2+&BROWSER=EXPLORER+&TOKEN=51461778+&TARGET=VIEW. September 10, 2013.
324 State of Arkansas. House Bill 1743, Act 902. An act to make an appropriation to the Department of Health for skin cancer education. 87th General Assembly. 2009. http://www.arkleg.state.ar.us/assembly/2009/R/Acts/Act902.pdf. September 10, 2013.
325 State of Florida. Code 381, Statute 981. Health awareness campaigns. Florida Senate. 2013. http://www.flsenate.gov/laws/statutes/2013/0381.981. September 10, 2013.
326 Geller A, Rutsch L, Kenausis K, Zhang Z. Evaluation of the SunWise school program. J Sch Nurs. 2003;19(2):93-99. [pmid: 12653621].
327 Kyle JW, Hammitt JK, Lim HW, et al. Economic evaluation of the U.S. Environmental Protection Agency's SunWise program: sun protection education for young children. Pediatrics. 2008;121(5):e1074-e1084. [pmid: 18450850].
328 Sinclair C, Makin JK. Implications of lessons learned from tobacco control for tanning bed reform. Prev Chronic Dis. 2013;10:e28. [pmid: 23449282].
329 National Conference of State Legislatures. Indoor tanning restrictions for minors - a state-by-state comparison. National Conference of State Legislatures website. http://www.ncsl.org/issues-research/health/indoor-tanning-restrictions.aspx. May 23, 2014.
330 AIM at Melanoma. 2014 indoor tanning legislation, 2014 state by state comparison. AIM at Melanoma website. http://www.aimatmelanoma.org/en/aim-for-a-cure/legislative-accomplishments-in-melanoma/2014-indoor-tanning.html. May 23, 2014.
331 Minnesota State Legislature, Minnesota House of Representatives. H.F. 2402 3rd Engrossment-88th Legislature (2013-2014). Omnibus health and human services policy bill. 2014.
332 Colorado Department of Public Health and Environment. Artificial tanning frequently requested information. Colorado Department of Public Health and Environment website. https://www.colorado.gov/pacific/cdphe/artificial-tanning-frequently-requested-information. July 11, 2014.
333 Kansas Board of Cosmetology. Statutes and regulations. Kansas Board of Cosmetology website. http://www.accesskansas.org/kboc/StatsandRegs.htm#tanninglaws. July 11, 2014.
334 Iowa Department of Public Health. Iowa Administrative Code, chapter 46. Minimum requirements for tanning facility. 2008. http://www.legis.iowa.gov/docs/ACO/chapter/641.46.pdf. January 30, 2014.
335 Guy GP, Berkowitz Z, Jones SE, et al. State indoor tanning laws and adolescent indoor tanning. Am J Public Health. 2014;104(4):e69-e74. [pmid: 24524515].
336 Gosis B, Sampson BP, Seidenberg AB, Balk SJ, Gottlieb M, Geller AC. Comprehensive evaluation of indoor tanning regulations: a 50-state analysis, 2012. J Invest Dermatol. 2014;134(3):620-627. [pmid: 23974917].
337 Hester EJ, Heilig LF, D'Ambrosia R, Drake AL, Schilling LM, Dellavalle RP. Compliance with youth access regulations for indoor UV tanning. Arch Dermatol. 2005;141(8):959-962. [pmid: 16103323].
338 Grewal SK, Haas AF, Pletcher MJ, Resneck JS Jr. Compliance by California tanning facilities with the nation's first statewide ban on use before the age of 18 years. J Am Acad Dermatol. 2013;69(6):883-889.e004. [pmid: 24120564].
339 Pichon LC, Mayer JA, Hoerster KD, et al. Youth access to artificial UV radiation exposure: practices of 3,647 U.S. indoor tanning facilities. Arch Dermatol. 2009;145(9):997-1002. [pmid: 19770438].
340 Forster JL, Lazovich D, Hickle A, Sorensen G, Demierre MF. Compliance with restrictions on sale of indoor tanning sessions to youth in Minnesota and Massachusetts. J Am Acad Dermatol. 2006;55(6):962-967. [pmid: 17097392].
341 Culley CA, Mayer JA, Eckhardt L, et al. Compliance with federal and state legislation by indoor tanning facilities in San Diego. J Am Acad Dermatol. 2001;44(1):53-60. [pmid: 11148477].
342 Louisiana Department of Health and Hospitals, Office of Public Health, Sanitarian Services Section, Food and Drug Unit. Rule pertaining to the regulation of tanning facilities and equipment. 1993. http://dhh.louisiana.gov/assets/oph/Center-EH/sanitarian/fooddrug/2896.pdf. January 27, 2014.
343 State of Maine. State of Maine rules relating to tanning facilities 10-144 CMR, chapter 223. Augusta, Maine. 2013. http://www.maine.gov/dhhs/mecdc/environmental-health/rad/documents/rules/2013%20tanning%20rules.pdf. January 27, 2014.
344 State of Rhode Island and Providence Plantations Department of Health. Rules and Regulations for the registration of tanning facilities (r23-68-tan). 2007. http://sos.ri.gov/dar_filing/regdocs/released/pdf/DOH/4827.pdf. January 30, 2014.
345 Florida Department of Health, Florida Division of Disease Control and Health Protection. Facility programs. Florida Health website. http://www.doh.state.fl.us/environment/community/tanning/index.html. September 30, 2013.
346 Iowa Department of Public Health. Tanning facilities. Iowa Department of Public Health website. http://www.idph.state.ia.us/Tanning/. September 30, 2013.
347 U.S. Food and Drug Administration. Consumer updates: the FDA sheds light on sunscreens. U.S. Food and Drug Administration website. http://www.fda.gov/forconsumers/consumerupdates/ucm258416.htm. January 31, 2014.
348 U.S. Food and Drug Administration. Title 21. Food and drugs. CFR 1040.20. Sunlamp products and ultraviolet lamps intended for use in sunlamp products. Fed Regist. 2013. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm?FR=1040.20. April 17, 2014.
349 U.S. Food and Drug Administration. FDA news release: FDA to require warnings on sunlamp products. U.S. Food and Drug Administration website. http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm399222.htm. June 4, 2014.
350 U.S. Food and Drug Administration. Rule. General and plastic surgery devices: reclassification of ultraviolet lamps for tanning, henceforth to be known as sunlamp products and ultraviolet lamps intended for use in sunlamp products. Fed Regist. 2014;79:31205-31214. [pmid: 24908684].
351 U.S. Food and Drug Administration. FDA's medical devices: classify your medical device. U.S. Food and Drug Administration website. http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/Overview/ClassifyYourDevice/default.htm. June 4, 2013.
352 U.S. Food and Drug Administration. Proposed rule. General and plastic surgery devices: reclassification of ultraviolet lamps for tanning, henceforth to be known as sunlamp products. Fed Regist. 2013;78:27117-27124.
353 Hirst N, Gordon L, Gies P, Green AC. Estimation of avoidable skin cancers and cost-savings to government associated with regulation of the solarium industry in Australia. Health Policy. 2009;89(3):303-311. [pmid: 18760857].
354 Hoerster KD, Garrow RL, Mayer JA, et al. Density of indoor tanning facilities in 116 large U.S. cities. Am J Prev Med. 2009;36(3):243-246. [pmid: 19215849].
355 Mayer JA, Woodruff SI, Slymen DJ, et al. Adolescents' use of indoor tanning: a large-scale evaluation of psychosocial, environmental, and policy-level correlates. Am J Public Health. 2011;101(5):930-938. [pmid: 21421947].
356 World Health Organization. Artificial Tanning Sunbeds: Risks and Guidance. Geneva, Switzerland. World Health Organization. 2003. http://www.who.int/uv/publications/en/sunbeds.pdf. June 5, 2013.
357 Mayer JA, Hoerster KD, Pichon LC, Rubio DA, Woodruff SI, Forster JL. Enforcement of state indoor tanning laws in the United States. Prev Chronic Dis. 2008;5(4):A125. [pmid: 18793513].
358 U.S. Food and Drug Administration. Policy on Maximum Timer Intervals and Exposure Schedule for Sunlamps. Rockville, MD. U.S. Food and Drug Administration, U.S. Dept of Health and Human Services. 1986.
359 Kwon HT, Mayer JA, Walker KK, Yu H, Lewis EC, Belch GE. Promotion of frequent tanning sessions by indoor tanning facilities: two studies. J Am Acad Dermatol. 2002;46(5):700-705. [pmid: 12004310].
360 Balaraman B, Biesbroeck LK, Lickerman SH, Cornelius LA, Jeffe DB. Practices of unregulated tanning facilities in Missouri: implications for statewide legislation. Pediatrics. 2013;131(3):415-422. [pmid: 23439910].
361 Federal Trade Commission. Indoor Tanning Association settles FTC charge that it deceived customers about skin cancer risks from tanning. Federal Trade Commission website. http://www.ftc.gov/opa/2010/01/tanning.shtm. June 4, 2013.
362 U.S. House of Representatives Committee on Energy and Commerce-Minority Staff. False and Misleading Health Information Provided to Teens by the Indoor Tanning Industry. Investigative Report. Prepared for Rep. Henry A. Waxman, Rep. Diana DeGette, Rep. Frank Pallone, Jr., Rep. Rosa L. DeLauro, and Rep. Carolyn Maloney. 2012. http://democrats.energycommerce.house.gov/sites/default/files/documents/False-Health-Info-by-Indoor-Tanning-Industry-2012-2-1.pdf. June 4, 2013.
363 Thomson CS, Twelves C. Legislation is needed to stop children using sunbeds. BMJ. 2009;339:b4643. [pmid: 19910405].
364 Dietrich AJ, Olson AL, Sox CH, Tosteson TD, Grant-Petersson J. Persistent increase in children's sun protection in a randomized controlled community trial. Prev Med. 2000;31(5):569-574. [pmid: 11071838].
365 Shih ST, Carter R, Sinclair C, Mihalopoulos C, Vos T. Economic evaluation of skin cancer prevention in Australia. Prev Med. 2009;49(5):449-453. [pmid: 19747936].
366 The Danish Cancer Society. Reduce your sun: the Danish sun safety campaign. The Danish Cancer Society website. http://www.cancer.dk/forebyg/skru-ned-for-solen/english/. January 11, 2014.
367 The Danish Cancer Society. Danish sun safety campaign reports. The Danish Cancer Society website. http://www.cancer.dk/skrunedforsolen/english/Research+and+evaluation/Reports/. January 11, 2014.
368 The Danish Cancer Society. Reduce your sun: campaign features. The Danish Cancer Society website. http://www.cancer.dk/skrunedforsolen/english/Campaign+features/. January 13, 2014.
369 Pawlak MT, Bui M, Amir M, Burkhardt DL, Chen AK, Dellavalle RP. Legislation restricting access to indoor tanning throughout the world. Arch Dermatol. 2012;148(9):1006-1012. [pmid: 22801924].
370 Olsen CM, Williams PF, Whiteman DC. Turning the tide? Changes in treatment rates for keratinocyte cancers in Australia 2000 through 2011. J Am Acad Dermatol. 2014;71(1):21-26. [pmid: 24685358].
371 Buller DB, Berwick M, Lantz K, et al. Randomized controlled trials on a smart phone mobile application delivering sun protection advice. Unpublished.
372 Buller DB, Berwick M, Shane J, Kane I, Lantz K, Buller MK. User-centered development of a smart phone mobile application delivering personalized real-time advice on sun protection. Transl Behav Med. 2013;3(3):326-334. [pmid: 24058385].
373 Hillhouse JJ, Baker MK, Turrisi R, et al. Evaluating a measure of tanning abuse and dependence. Arch Dermatol. 2012;148(7):815-819. [pmid: 22801615].
374 Banerjee SC, Hay JL, Geller AC, Gagne JJ, Frazier AL. Quitting the “cancer tube”: a qualitative examination of the process of indoor tanning cessation. Transl Behav Med. 2014;4(2):209-219. [pmid: 24904705].
375 Hart KM, Demarco RF. Primary prevention of skin cancer in children and adolescents: a review of the literature. J Pediatr Oncol Nurs. 2008;25(2):67-78. [pmid: 18272782].
376 Cardinez CJ, Cokkinides VE, Weinstock MA, O'Connell MC. Sun protective behaviors and sunburn experiences in parents of youth ages 11 to 18. Prev Med. 2005;41(1):108-117. [pmid: 15917001].
377 Dexheimer JW, Talbot TR, Sanders DL, Rosenbloom ST, Aronsky D. Prompting clinicians about preventive care measures: a systematic review of randomized controlled trials. J Am Med Inform Assoc. 2008;15(3):311-320. [pmid: 18308989].
378 U.S. Department of Labor. Findings from the National Agricultural Workers Survey (NAWS) 2001-2002. A Demographic and Employment Profile of United States Farm Workers. Research Report, No. 9. Washington, DC. U.S. Dept of Labor. 2005. http://www.doleta.gov/agworker/report9/naws_rpt9.pdf. May 2, 2014.
379 Janda M, Youl P, Marshall AL, Soyer HP, Baade P. The HealthyTexts study: a randomized controlled trial to improve skin cancer prevention behaviors among young people. Contemp Clin Trials. 2013;35(1):159-167. [pmid: 23557730].
380 Heydenreich J, Wulf HC. Miniature personal electronic UVR dosimeter with erythema response and time-stamped readings in a wristwatch. Photochem Photobiol. 2005;81(5):1138-1144. [pmid: 15850424].
381 Moss C. This bracelet will warn you when you've been in the sun for too long. Business Insider. 2014. http://www.businessinsider.com/netatmo-june-bracelet-2014-1. March 24, 2014.
382 Carli P, Crocetti E, Chiarugi A, et al. The use of commercially available personal UV-meters does cause less safe tanning habits: a randomized-controlled trial. Photochem Photobiol. 2008;84(3):758-763. [pmid: 18086243].
383 American Academy of Dermatology. Melanoma reporting to state cancer registries. http://www.aad.org/File%20Library/Global%20navigation/Education%20and%20quality%20care/State%20cancer%20registries/state-cancer-registries-laws-and-requirements.pdf. February 2, 2014.
384 Cartee TV, Kini SP, Chen SC. Melanoma reporting to central cancer registries by U.S. dermatologists: an analysis of the persistent knowledge and practice gap. J Am Acad Dermatol. 2011;65(5 suppl 1):S124.e001-S124.e009. [pmid: 22018061].
385 Cockburn M, Swetter SM, Peng D, Keegan THM, Deapen D, Clarke CA. Melanoma underreporting: why does it happen, how big is the problem, and how do we fix it?. J Am Acad Dermatol. 2008;59(6):1081-1085. [pmid: 19022107].
386 Centers for Disease Control and Prevention. Meaningful use of electronic health records. National Program of Cancer Registries, Centers for Disease Control and Prevention website. http://www.cdc.gov/cancer/npcr/meaningful_use.htm. December 12, 2013.
387 Centers for Disease Control and Prevention. Stage 2 meaningful use fact sheet. Public health reporting objectives. Centers for Disease Control and Prevention website. http://www.cdc.gov/phin/library/PHIN_Fact_Sheets/Stage%202%20Fact%20Sheet-09_03_2013.pdf. February 25, 2014.
388 Mariotto AB, Yabroff KR, Shao Y, Feuer EJ, Brown ML. Projections of the cost of cancer care in the United States: 2010-2020. J Natl Cancer Inst. 2011;103(2):117-128. [pmid: 21228314].
389 Centers for Disease Control and Prevention. Behavioral Risk Factor Surveillance System. Centers for Disease Control and Prevention website. http://www.cdc.gov/brfss/. February 24, 2014.
390 Internal Revenue Service. Affordable Care Act tax provisions. Internal Revenue Service website. http://www.irs.gov/uac/Affordable-Care-Act-Tax-Provisions. June 4, 2013.
391 Jain N, Rademaker A, Robinson JK. Implementation of the federal excise tax on indoor tanning services in Illinois. Arch Dermatol. 2012;148(1):122-124. [pmid: 22250250].
392 U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General. Atlanta, GA. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services. 2012. http://www.surgeongeneral.gov/library/reports/preventing-youth-tobacco-use/full-report.pdf. February 24, 2014.
393 WebShade website. Changing the way we think about shade. http://www.webshade.com.au/index.html. Nov 20, 2013.
394 Toronto Cancer Prevention Coalition. Shade Guidelines. Toronto, Canada. Toronto Cancer Prevention Coalition. 2010. http://www1.toronto.ca/city_of_toronto/toronto_public_health/healthy_public_policy/tcpc/files/pdf/shade_guidelines.pdf. March 7, 2014.
395 Scully M, Makin J, Maloney S, Wakefield M. Changes in coverage of sun protection in the news: threats and opportunities from emerging issues. Health Educ Res. 2014;29(3):378-387. [pmid: 24650946].
396 Community Preventive Services Task Force. Preventing skin cancer: multicomponent community-wide interventions (abbreviated). The Guide to Community Preventive Services website. http://www.thecommunityguide.org/cancer/skin/community-wide/multicomponent.html. January 17, 2014.
397 Cancer Council Victoria. Skin Cancer Prevention: A Blue Chip Investment in Victoria. Victoria, Australia. Cancer Council Victoria, SunSmart, Centre for Behavioural Research in Cancer. 2008.
398 Sinclair C, Foley P. Skin cancer prevention in Australia. Br J Dermatol. 2009;161(suppl 3):116-123. [pmid: 19775367].
399 Geller AC, Glanz K, Shigaki D, Isnec MR, Sun T, Maddock J. Impact of skin cancer prevention on outdoor aquatics staff: the Pool Cool program in Hawaii and Massachusetts. Prev Med. 2001;33(3):155-161. [pmid: 11522155].
400 Rand CM, Blumkin A, Szilagyi PG. Electronic health record use and preventive counseling for U.S. children and adolescents. J Am Med Inform Assoc. 2014;21(e1):e152-e156. [pmid: 24013091].
401 Pageler NM, Longhurst CA, Wood M, et al. Use of electronic medical record-enhanced checklist and electronic dashboard to decrease CLABSIs. Pediatrics. 2014;133(3):e738-e746. [pmid: 24567021].
402 Iglar K, Katyal S, Matthew R, Dubey V. Complete health checkup for adults: update on the preventive care checklist form. Can Fam Physician. 2008;54(1):84-88. [pmid: 18208964].
403 Community Preventive Services Task Force. Preventing skin cancer: primary and middle school interventions. Task Force finding and rationale statement. The Guide to Community Preventive Services website. http://www.thecommunityguide.org/cancer/skin/education-policy/RRprimaryandmiddleschools.html. January 30, 2014.
404 Merlino LA, Sullivan KJ, Whitaker DC, Lynch CF. The independent pathology laboratory as a reporting source for cutaneous melanoma incidence in Iowa, 1977-1994. J Am Acad Dermatol. 1997;37(4):578-585. [pmid: 9344197].
405 Gallagher RP, Bajdik CD, Fincham S, et al. Chemical exposures, medical history, and risk of squamous and basal cell carcinoma of the skin. Cancer Epidemiol Biomarkers Prev. 1996;5(6):419-424. [pmid: 8781736].
406 Cancer Council Australia. SunSmart position statement on window tinting. Cancer Council Australia wiki website. http://wiki.cancer.org.au/prevention/Position_statement_-_Tinted_windows. April 11, 2014.
407 Goldstein NJ, Cialdini RB. Using social norms as a lever of social influence. Pratkanis AR, editor. The Science of Social Influence: Advances and Future Progress. New York, NY. Psychology Press. 2007:167-192.
408 Stryker JE, Lazovich D, Forster JL, Emmons KM, Sorensen G, Demierre MF. Maternal/female caregiver influences on adolescent indoor tanning. J Adolesc Health. 2004;35(6):528.e001-528.e009. [pmid: 15581535].
409 Boyers L, Karimkhani C, Crane LA, Asdigian N, Hollonds A, Dellavalle RP. Buying indoor tanning with university debit cards. J Am Acad Dermatol. 2014;71(1):199-201. [pmid: 24947697].
410 Brouse CH, Basch CE, Neugut AI. Warning signs observed in tanning salons in New York city: Implications for skin cancer prevention. Prev Chronic Dis. 2011;8(4):A88. [pmid: 21672412].
411 U.S. Food and Drug Administration Center for Devices and Radiological Health, Medical Devices Advisory Committee. General and plastic surgery devices panel: transcript. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/MedicalDevices/MedicalDevicesAdvisoryCommittee/GeneralandPlasticSurgeryDevicesPanel/UCM210232.pdf. June 4, 2013.
412 Song F, Qureshi AA, Giovannucci EL, et al. Risk of a second primary cancer after non-melanoma skin cancer in white men and women: a prospective cohort study. PLoS Med. 2013;10(4):e1001433. [pmid: 23630459].
413 Ong EL, Goldacre R, Hoang U, Sinclair R, Goldacre M. Subsequent primary malignancies in patients with nonmelanoma skin cancer in England: a national record-linkage study. Cancer Epidemiol Biomarkers Prev. 2014;23(3):490-498. [pmid: 24609853].
414 Wolff K, Johnson BE, Saavedra AP. Precancerous lesions and cutaneous carcinomas. Fitzpatrick's Color Atlas and Synopsis of Clinical Dermatology. 7th ed. New York, NY. McGraw-Hill. 2013.
415 Honigsmann H. Erythema and pigmentation. Photodermatol Photoimmunol Photomed. 2002;18(2):75-81. [pmid: 12147040].
416 Goldsmith LA, Fitzpatrick TB. Fitzpatrick's Dermatology in General Medicine. 8th ed. New York, NY. McGraw-Hill Professional. 2012.
417 U.S. Preventive Services Task Force. Screening for skin cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;150(3):188-193. [pmid: 19189908].
418 Katalinic A, Waldmann A, Weinstock MA, et al. Does skin cancer screening save lives?: an observational study comparing trends in melanoma mortality in regions with and without screening. Cancer. 2012;118(21):5395-5402. [pmid: 22517033].
419 Bordoni A, Leoni-Parvex S, Peverelli S, Mazzola P, Mazzucchelli L, Spitale A. Opportunistic screening strategy for cutaneous melanoma does not change the incidence of nodular and thick lesions nor reduce mortality: a population-based descriptive study in the European region with the highest incidence. Melanoma Res. 2013;23:402-407.
420 Glanz K, Saraiya M, Wechsler H, Centers for Disease Control and Prevention. Guidelines for school programs to prevent skin cancer. MMWR Recomm Rep. 2002;51(RR-4):1-18. [pmid: 11995901].
421 Centers for Disease Control and Prevention. Sun Safety for America's Youth Toolkit. Atlanta, GA. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services. 2009. http://www.cdc.gov/cancer/skin/pdf/toolkit/SunSafetyToolkit_MainText.pdf. August 9, 2013.
422 Centers for Disease Control and Prevention. Stories of Success: National Comprehensive Cancer Control Program: Comprehensive Cancer Control in Action. Atlanta, GA. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services. 2010. http://www.cdc.gov/cancer/ncccp/pdf/success/SuccessStories.pdf. April 13, 2013.
423 Jones SE, Saraiya M, Miyamoto J, Berkowitz Z. Trends in sunscreen use among U.S. high school students: 1999-2009. J Adolesc Health. 2012;50(3):304-307. [pmid: 22325137].
424 National Cancer Institute. Behavioral Research, Cancer Control and Population Sciences: about Health Behaviors Research Branch (HBRB). National Cancer Institute website. http://cancercontrol.cancer.gov/brp/hbrb/about.html. February 3, 2014.
425 Jorgensen CM, Wayman J, Green C, Gelb CA. Using health communications for primary prevention of skin cancer: CDC's Choose Your Cover campaign. J Womens Health Gend Based Med. 2000;9(5):471-475. [pmid: 10883937].
426 Given LS, Black B, Lowry G, Huang P, Kerner JF. Collaborating to conquer cancer: a comprehensive approach to cancer control. Cancer Causes Control. suppl 1. 2005;16:3-14. [pmid: 16208570].
427 Centers for Disease Control and Prevention. Comprehensive Cancer Control Plans: A Content Review. Atlanta, GA. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services. 2005. http://www.cdc.gov/cancer/ncccp/pdf/CCC_Plans_Content_Review.pdf. May 16, 2013.
428 Centers for Disease Control and Prevention. Chronic Disease Management Information System, DP12-1205 National Comprehensive Cancer Control Program programmatic data, 2012–2013. Atlanta, GA. Centers for Disease Control and Prevention.
429 Lim HW, James WD, Rigel DS, Maloney ME, Spencer JM, Bhushan R. Adverse effects of ultraviolet radiation from the use of indoor tanning equipment: time to ban the tan. J Am Acad Dermatol. 2011;64(5):893-902. [pmid: 21496701].
430 Federal Trade Commission. Indoor tanning. Federal Trade Commission website. http://www.consumer.ftc.gov/articles/0129-indoor-tanning. June 4, 2013.
431 U.S. Environmental Protection Agency, SunWise Program. UV index. U.S. Environmental Protection Agency website. http://www.epa.gov/sunwise/uvindex.html. April 19, 2013.
432 National Weather Service: Climate Prediction Center. Stratosphere: UV index. Climate Prediction Center website. http://www.cpc.ncep.noaa.gov/products/stratosphere/uv_index/index.html. April 19, 2013.
433 Occupational Safety and Health Act of 1970, Public Law 91-596. 84 Statute 1590 (1970).
434 U.S. Department of Labor, Occupational Safety Health Administration. Standard interpretations: 1910.97; 1910.1096. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=INTERPRETATIONS&p_id=24755. December 12, 2013.
435 U.S. Department of Labor, Occupational Safety and Health Administration. Water. Rest. Shade. The work can't get done without them. Protective measures to take at each risk level. Occupational Safety and Health website. http://www.osha.gov/SLTC/heatillness/heat_index/protective_high.html. December 12, 2013.
436 National Weather Service. Public information notice: excessive heat and sun safety guidance for 2013 season. National Weather Service website. http://www.nws.noaa.gov/os/notification/pns13don-t_fry_day.txt. February 2, 2014.
437 U.S. Preventive Services Task Force. USPSTF A and B recommendations. U.S. Preventive Services Task Force website. http://www.uspreventiveservicestaskforce.org/uspstf/uspsabrecs.htm. February 3, 2014.
438 U.S. Department of Labor. FAQs about Affordable Care Act implementation part XII. U.S. Department of Labor website. http://www.dol.gov/ebsa/faqs/faq-aca12.html. February 3, 2014.