# Gaps in Research and Surveillance

Internationally, research has provided strong evidence about what works to reduce the risk of skin cancer, and there is a growing body of evidence in the United States. However, additional research and surveillance are needed to maximize the success of future skin cancer prevention efforts. Important strides have been made in skin cancer prevention in the United States, but they have not been sufficient to curb the rising rates of skin cancer incidence. Social and behavioral research can help us better understand some issues, such as ongoing high rates of sunburn despite improvements in sun protection and ongoing high rates of indoor tanning despite evidence that it is a human carcinogen. More information is needed regarding effective message framing and effective policies to promote behavior change.

Finally, reliable data are needed to measure the effect of prevention efforts. Many skin cancer cases are not being captured by current surveillance systems, and current behavioral surveillance systems may not be adequate to track the effect of state and local initiatives, such as indoor tanning restrictions for minors. Identifying areas where information is lacking is important in order to improve efforts to prevent skin cancer. This section details the gaps in what is currently known. The “Calls to Action” section (page 46) will propose strategies for filling these gaps.

## Individuals

Although surveillance data indicate that some sun protection practices have increased, these behaviors have not been associated with a reduction in the incidence of sunburn.226 These data indicate inadequate use of sun protection among Americans and are cause for concern. Research is needed to increase understanding of the factors that underlie inadequate sun protection behaviors and to identify strategies to increase adoption of sun protection practices beyond sunscreen use. Current recommended intervals for reapplication may not maximize the protectiveness of modern sunscreens, and more research that accounts for how sunscreens are actually applied in real-world situations would help guide future recommendations.240

Specific information is needed about effective messaging to influence positive behavior change related to skin cancer prevention for specific groups, such as frequent tanners, event tanners (those who tan before a special occasion like a prom or wedding), athletes, people concerned about vitamin D deficiency, males versus females, and different racial and ethnic groups. More research on effective communication would allow for specific messaging in education and communication interventions. Similarly, testing prevention messages would ensure that only the most effective interventions are disseminated and that they are suitably tailored for specific groups.

New technologies, such as personalized mobile applications (or “apps”) that measure UV exposure, may provide opportunities to address messages to people concerned about sun protection.371,372 Behavioral counseling has been shown to be effective, but these studies were only conducted among female undergraduate tanners. More research is needed to determine effectiveness among broader populations, especially frequent tanners.306

Better understanding is needed of the potentially reinforcing properties of indoor tanning, such as the release of endorphins when the skin is exposed to UV radiation.270-272 By adapting questionnaires used for substance-related addiction disorders, researchers found that study participants who report regular, more frequent indoor tanning tended to report reactions to tanning such as relaxation, pain relief, stress relief, and a sense of well-being or euphoria.373 More research is needed to understand whether these reactions to indoor tanning can cause users to feel physically or psychologically dependent on indoor tanning. In turn, alternative approaches may be needed to intervene for these indoor tanners, who may differ from the broader population.374

## Parents

For children, adequate sun protection depends largely on their parents' attitudes and behaviors.375,376 Research has also shown that parental acceptance of tanning has a strong influence on adolescent tanning behavior.275 More information is needed to assess parents' attitudes and behaviors regarding sun protection and indoor tanning (for themselves and for their children), as well as parents' awareness of their children's use of sun protection and tanning behaviors. Although parental modeling of tanning behavior is a strong predictor of their children's tanning behavior, the prevalence of parents' indoor tanning with their children is unknown.275 Strategies for involving parents in prevention efforts for children should be formulated and evaluated.

## Clinicians

Currently, little information exists on whether clinicians follow USPSTF recommendations for behavioral counseling for skin cancer prevention. Surveys or other systems are needed to monitor clinicians' counseling practices. Given the large time demands on clinicians, resources and tools are needed to provide guidance on best practices that clinicians can fit into their short time with patients. These resources should include information on how to identify patients at high risk and give them appropriate behavioral counseling on how to prevent skin cancer. Providing computer prompts through electronic health record (EHR) systems may increase clinicians' delivery of preventive care, including behavioral counseling on skin cancer prevention.377

Skin cancers detected at earlier stages are easier to treat than those diagnosed later.6,31 More research is needed to determine who is most likely to benefit from screening (see Appendix 3), as well as effective ways to increase awareness and early detection.

## Schools

Skin cancer prevention interventions that use education and policy approaches in elementary and middle schools and child care centers have been found to be effective.306 More information is needed on the long-term effect of these interventions on sun-protective behaviors and sunburn. More evidence is needed to determine the effectiveness of similar interventions in high school, college, and university settings. Furthermore, evidence is needed to identify similar school-based strategies that could effectively address indoor tanning and complement other efforts to reduce indoor tanning, such as legislation and mass media campaigns.

Photo courtesy of Queensland Department of Health

Photo of school girls wearing wide-brimmed hats, standing along a fence. Photo courtesy of Queensland Department of Health.

## Outdoor Workers

Better understanding of how to reduce the risk of skin cancer among outdoor workers is needed. Although employers are legally responsible for ensuring the protection of their workers, they are not specifically required to provide sun protection, such as sunscreen, hats, or long-sleeved shirts. Understanding the costs and benefits of employer-provided protection would help determine its effectiveness and cost-effectiveness. More information on the types and prevalence of sun protection methods among outdoor workers is needed, as well as information on potential differences in language and culture.378

Photo of an agricultural worker picking cabbage in a field, wearing a long-sleeved shirt with dark fabric and a wide-brimmed hat.

## Communities and Social Networks

Additional research can provide information to communities on how to maximize the protective effects of environmental changes in the community, such as how adding shade structures will affect sun protection, which improvements are most cost-effective, and where and how shade structures could be best used. Best practices on community shade structures, similar to guidelines for schools, may be needed. Surveys that ask about common sources of sun exposure would help identify sites where shade would be most effective.

Researchers need to conduct further studies to identify ways to shift social norms around tanned skin and sun protection and increase sun protection methods beyond sunscreen use. Social network research in general and social media research in particular could help capture real-time responses to media stories and campaigns. This research could help monitor attitudes on tanned (or untanned) appearance. In turn, social marketing may provide opportunities for wide dissemination of individualized messages about skin cancer prevention. Interventions that use text messages have also shown promise in improving prevention behaviors and may provide opportunities for skin cancer prevention.379 New wearable UV sensor technology may provide additional opportunities for research on the effectiveness of prevention strategies, but their effect on sun protection practices is unknown.104,380-382

## Indoor Tanning Legislation and Multilevel Influence

Evidence on the effectiveness of indoor tanning legislation suggests that different laws may have different effects on tanning behaviors.335 The effects of specific laws, such as prohibitions on tanning for youth younger than age 18 years or enhanced warning labels, are unclear. Recent studies have found that age restrictions appear to be associated with decreased tanning among youth.335,337 Evidence regarding the effects of other policies and legislation on indoor tanning is limited, and some studies that have attempted to examine the relationship between the presence of local laws and indoor tanning have failed to find an association.355 The lack of evidence may be due, in part, to challenges in surveillance and monitoring of indoor tanning at the state level; wide variation in the stringency, compliance, and enforcement of laws and regulations; and the relatively recent adoption of restrictive laws and regulations.335,355

Monitoring changes in tanning behaviors over time (both indoor tanning and sunbathing) as new indoor tanning legislation is adopted can help document the effects of such legislation. It can also guide future policies and identify unintended consequences, such as replacement of tanning in salons with indoor tanning at home or sunbathing. Adequate compliance, monitoring, and enforcement will be needed to have the greatest effect on behavior and policies.

The lack of a comprehensive and multilevel approach to reducing indoor tanning may also be a barrier to successful policy efforts. Without reinforcement by other legislative or regulatory organizations, certain restrictions on indoor tanning may be difficult to enforce. For example, without adequate controls to ensure that minors do not tan indoors on their own, age bans on tanning are easily circumvented.356 WHO recommends banning the sale of unsupervised indoor tanning devices as a complement to restricting minors' use of tanning beds.356 The prevalence of unsupervised tanning and home use of tanning beds is also not well-documented, and surveys or other systems are needed to monitor these types of tanning behaviors.

Social norms regarding tanning, the desire to have tanned skin, and misconceptions about the health effects of indoor tanning are more likely to be influenced if policy approaches are coordinated with comprehensive approaches at local, state, and national levels.260,262 Research is needed to identify the effective combination of intervention components at different levels of influence that can be tailored to specific groups and widely disseminated.260,262

## Surveillance

### Cancer Surveillance

Counts and prevalence of people treated for NMSCs have been estimated from individual-level data from the Medical Expenditure Panel Survey,7,10 but surveillance data on these cancers are not generally available. Melanoma data are collected by population-based cancer registries, and these data are needed for long-term evaluation of prevention efforts. Doctors diagnosing or treating in situ and invasive melanomas are required by law to report cases to central cancer registries.383 Hospitals generally have systems set up to report inpatient cases. However, melanomas diagnosed and treated in outpatient settings are frequently underreported, highlighting the need for improved awareness of proper reporting requirements among doctors, especially dermatologists.384,385

In 2009, the Centers for Medicare & Medicaid Services (CMS) established incentive programs to encourage health care providers to adopt, implement, and upgrade the use of certified EHRs in different stages. (For more information about EHRs, visit http://www.cms.gov/Regulations-and-Guidance/Legislation/EHRIncentivePrograms/Stage_2.html.) Reporting cancer cases to a central cancer registry is included in Stage 2 of the incentive program, so providers have an additional incentive to report melanoma cases beyond compliance with state law.386,387 The most recent estimates of melanoma and NMSC incidence were conducted in 2011.^7,9,53,388^ New analyses are needed to show melanoma trends from more recent years, and new methods are needed to better estimate NMSCs (which are not included in cancer registry collection).

### Behavioral Surveillance

Some information on sun-safety behaviors and indoor tanning is included in surveillance system surveys, but more could be done to use these systems to advance surveillance of behaviors related to skin cancer risk. For example, the Behavioral Risk Factor Surveillance System (BRFSS) is a state-based, random-digit–dialed telephone survey of the noninstitutionalized, U.S. civilian adult population aged 18 years or older. It is administered annually to households with landline and cellular telephones by state health departments in collaboration with CDC.389 This nationally representative survey is designed to enable prevalence estimates at the state level and, in some instances, at the local or metropolitan level.

Photo of a toddler wearing a wide-brimmed hat and playing in a sprinkler at a park.

Inclusion of questions about sun protection and indoor tanning on the BRFSS would allow better state-specific analysis of indoor tanning prevalence and sun protection behavior, which would provide more information on the effect of interventions. Likewise, the national YRBS is designed to be a nationally representative sample of high school students. It measures indoor tanning frequency and sunscreen use, but does not currently measure other sun protection behaviors, such as use of protective clothing, hats, and shade. Furthermore, the survey's sample design does not yield state-specific measures.

Inclusion of indoor tanning questions on state YRBS questionnaires would allow for evaluation of state policies. However, only a few states have added such questions to their surveys, making it difficult to measure prevalence of indoor tanning and monitor the effect of indoor tanning restrictions for minors at state levels. This lack of data at the state level also poses barriers for state-level planning and evaluation.

In addition, little information is available on intentional outdoor UV exposure behaviors (sunbathing or seeking a tan). Measuring this behavior would help researchers quantify any unintended consequences of changes to indoor tanning legislation or attitudes. Surveillance systems that monitor indoor tanning attitudes and beliefs among the U.S. population and among indoor tanners are also needed. Questions designed to collect this information could be added to existing surveys, such as the Health Information National Trends Survey (HINTS), the National Survey of Family Growth, or national panel surveys such as HealthStyles.

### Surveillance of Environmental Exposure

Little information is available on general outdoor exposure to UV radiation that is experienced in the course of routine activities, such as playing sports, engaging in physical activity, gardening, or walking a dog. Research on personalized UV sensor technology and Global Positioning System devices could be used to better capture UV exposure among individuals and allow for more accurate measurement of individual UV exposure in the near future.104,371,372,381 Research is needed to determine the best way to use existing technology or expand the way current systems work together. Doing so may improve surveillance estimates of UV exposure, guide intervention efforts, and possibly enhance prevention behavior.

## Vitamin D and Sun Protection

More research on the relationship between vitamin D and sun protection behaviors is needed. Although guidelines exist to identify levels of insufficiency and deficiency, optimal serum concentrations of vitamin D are a matter of scientific debate and most likely vary among individuals.173 As previously discussed, FDA concluded in 2011 that clinical studies on the effect of sunscreen use on vitamin D concentrations were inconclusive.187 Although not enough evidence exists currently to determine whether sunscreen use alone can lead to vitamin D deficiency,187 improving sun protection across the population could potentially lead to reduced vitamin D concentrations for some individuals if not compensated for by vitamin D intake from diet or supplements.82,86,142,187 If populationwide skin cancer prevention programs were implemented in the future, surveillance data from the National Health and Nutrition Examination Survey (NHANES) could be used to monitor vitamin D serum concentrations in the population and document any unintended consequences of skin cancer prevention interventions, such as increases in vitamin D deficiency.

## Economic Analysis

Estimates of the health and economic benefits of reducing risk factors for skin cancer and the subsequent reductions in skin cancer incidence and mortality are needed to justify and guide current and future prevention efforts. For example, economic modeling could be performed to examine the number of skin cancer cases averted and the costs saved by implementing various indoor tanning policies and other communitywide efforts.

In addition, the effect of economic interventions, such as the 10% excise tax levied on indoor tanning services through the Affordable Care Act, is largely unknown.390,391 The only evidence of its effect was limited to tanning salons in one state.391 A national study is needed to examine the effect of the excise tax and how increases in the price of indoor tanning could affect its use, similar to studies conducted on tobacco taxes.392

## Potential Unintended Consequences of Interventions

As with any intervention, increasing sun protection in the population could have unintended consequences. Some people may become sensitized to the chemicals in sunscreens, and increased sunscreen use could lead to increased sensitization, resulting in urticaria (hives) or allergic contact dermatitis.231 Restrictions on indoor tanning without changes to social norms about the desirability of tanned skin might encourage tanners to seek the sun outdoors, to tan in less-regulated settings (such as in homes), or to use sunless tanning.260 Ongoing efforts are needed to monitor the effects of skin cancer prevention efforts, including unintentional and potentially harmful effects, such as reductions in vitamin D concentrations in the population or reductions in physical activity.