# Foreword from the Acting Surgeon General, U.S. Department of Health and Human Services

Photo of Boris D. Lushniak, Acting Surgeon General of the U.S. Department of Health and Human Services.

The rates of skin cancer in our nation are increasing, creating a serious public health concern we cannot ignore. As both a medical doctor and a public health official, I see that now is the time for a comprehensive approach to prevent skin cancer, bringing together community partners, business leaders, government agencies, and individuals for a common cause. As a dermatologist, I consider myself fortunate to be a part of this effort and am proud to release this Call to Action to Prevent Skin Cancer.

By acknowledging that most skin cancers can be prevented and bringing together partners with a unified, dynamic approach, we are taking concrete steps to support a healthier country. We know there are many strategies that work to protect us from ultraviolet (UV) radiation from the sun, and we need to use them. For example, we recommend that communities provide shade in recreational and play areas to help protect children from overexposure to UV radiation, that businesses increase availability of sun protection for outdoor workers, that policy makers promote policies for shade planning in land use development, and that health providers counsel patients on the importance of using sun protection.

Each day, thousands of teens are exposing themselves, unprotected, to harmful UV radiation from tanning beds, but only 10 states currently have laws in place to prevent this practice for youth younger than age 18 years. Together, we must communicate the risks in a clear and effective way to family, friends, and others to help them understand their role in preventing skin cancer. We must also support policy and environmental changes that protect both children and adults. These types of strategies, and many more, are described in the Call to Action.

The word prevention cannot be emphasized enough with our efforts. In a world of epidemics, outbreaks, and growing rates of cancer and other chronic diseases, we can sometimes feel that good health eludes us. With this Call to Action, we are promoting straightforward steps that will incorporate skin cancer prevention into our everyday lives. The potential exists for a large return on our investment; the cost both in illness and death and in dollars is great. With strategies that improve our understanding of the risks and support increased opportunities for skin cancer protection, we can truly have a significant impact on skin cancer-related illness, death, and health care costs.

Join me in promoting and sustaining our efforts to make skin cancer prevention a reality. We can be a nation that is active, healthy, and safe from skin cancer.

- Boris D. Lushniak, M.D., M.P.H.
  Rear Admiral, U.S. Public Health Service
  Acting Surgeon General
  U.S. Department of Health and Human Services