# Message from the Assistant Secretary for Health, U.S. Department of Health and Human Services

Photo of Howard K. Koh, Assistant Secretary for Health of the U.S. Department of Health and Human Services.

Skin cancer is the most commonly diagnosed cancer in the United States, yet most cases are preventable. Every year in the United States, nearly 5 million people are treated for skin cancer, at an estimated cost of $8.1 billion. Melanoma, the most deadly form of skin cancer, causes nearly 9,000 deaths each year. Despite recent efforts to address risk factors, skin cancer rates continue to rise.

While those with lighter skin are more susceptible, anyone can get skin cancer—and it can be serious, even deadly. As a skin oncologist who worked in this field for many years, I have cared for both young and old with skin cancers. Almost all of the conditions were caused by unnecessary ultraviolet (UV) radiation exposure, usually from excessive time in the sun or from the use of indoor tanning devices.

It is alarming that every year, nearly one out of every three young white women aged 16–25 engages in indoor tanning. It's important to shatter the myth that tanned skin is a sign of health. And a “base” tan is not a “safe” tan. Tanned skin is damaged skin. Understanding the risk of UV exposure is crucial to protecting ourselves and our loved ones.

That is why The Surgeon General's Call to Action to Prevent Skin Cancer is important for all of us. It outlines action steps we can all take—as individuals, parents, educators, employers, policy makers, health care professionals, and communities—to reverse this alarming trend.

As a nation, we can all do more to address skin cancer as a serious public health challenge. I urge everyone to find out more about the risk of skin cancer—and what we all can do to prevent it.

- Howard K. Koh, M.D., M.P.H.
  Assistant Secretary for Health
  U.S. Department of Health and Human Services