# Conclusion

With this Call to Action, the U.S. Surgeon General emphasizes the need to act now to solve the major public health problem of skin cancer. Despite efforts to address skin cancer risk factors, skin cancer rates, including rates of melanoma, have continued to increase in the United States.1,13-17 More than one-third of Americans report being sunburned in the past year,226 and indoor tanning is common among some groups.132,133 We need to work together to address skin cancer as a public health problem. We know that comprehensive, communitywide efforts to prevent skin cancer can work, with adequate support and a unified approach.

To reduce skin cancers in the population, people must get the information they need to make informed choices about sun protection, policies must support these efforts, youth must be protected from harms of indoor tanning, and adequate investments need to be made in skin cancer research and surveillance. Achieving these goals will not be a small task. It will require dedication, ingenuity, skill, and the concerted efforts of many partners in prevention across many different sectors. Many of these partners are already enthusiastically involved, but greater coordination and support are needed to increase the reach of their efforts. The strategies outlined in this document are the next steps. We must act with urgency to stop the ever-increasing incidence of skin cancers in the United States.

Photo of an older man wearing a wide-brimmed hat and sunglasses.