# Calls to Action

This section presents five strategic goals to support skin cancer prevention in the United States. Federal, state, tribal, local, and territorial governments; members of the business, health care, and education sectors; community, nonprofit, and faith-based organizations; and individuals and families are all essential partners in this effort. Strategies that change the context or environment to support healthy choices generally have greater reach and are more effective at the population level than strategies focused on individual behavior.314

This section also provides education and communication strategies, which will likely be most effective if used in conjunction with changes to the social context and environment. Aligning and coordinating efforts for skin cancer prevention across a wide range of partners is central to achieving success. Involving partners across disciplines, sectors, and institutions will be essential to addressing the rising incidence of skin cancers in the United States.

PARTNERS IN PREVENTION

■ Federal, state, tribal, local, and territorial governments.
■ Businesses, employers, and labor representatives.
■ Health care systems, insurers, and clinicians.
■ Early learning centers, schools, colleges, and universities.
■ Community, nonprofit, and faith-based organizations.
■ Individuals and families.

## Goal 1 Increase Opportunities for Sun Protection in Outdoor Settings

Increasing opportunities for sun protection in outdoor settings can make healthy sun-safe behaviors the default choice and help Americans enjoy their time outdoors safely with minimal effort. Changing the context for sun protection may also contribute to changing social norms regarding the necessity of sun protection while outdoors.

### Strategy 1A Increase shade in outdoor recreational settings

When spending time outdoors, Americans can be exposed to high levels of UV radiation. Communities can increase the availability of shade in recreational settings, such as parks and sports fields, to provide passive protection and increase comfort levels. Strategically planting trees or building structures to shade frequently used areas can protect people from heat as well as UV radiation and increase their comfort while outdoors. A shade audit is a systematic process to determine how much shade is currently available on a site, where more is needed, and where to place trees and shade structures to be most effective.308,393,394 Existing shade audit, planning, and policy tools, such as CDC's Shade Planning for America's Schools, could potentially be adapted for broader community use.308,394 New technologies might offer the possibility of strategic shade planning with minimal resources and investment.393 Changing the environment by increasing shade can help parents and caregivers adequately protect their children from excessive sun exposure. Even one bad sunburn in childhood increases risk of melanoma later in life.87 Protecting children can be difficult, as they may be resistant to wearing additional clothing, hats, and sunglasses. Sunscreen can be difficult to apply and reapply, especially for younger children.

Key partners in prevention include federal, state, tribal, local, and territorial governments; businesses and employers, especially urban planners and architects; early learning centers, schools, colleges, and universities; community, nonprofit, and faith-based organizations; and individuals and families. These partners can support efforts to do the following:

■ Provide shade from trees, nearby buildings, or structures specifically designed to block the sun, such as canopies and umbrellas.
■ Use a shade audit process or tool308,393,394 to help ensure effective shade planning.
■ Adapt existing shade planning tools308,393,394 for broader community use and disseminate these tools widely.
■ Ensure ample availability of shade in recreational and play areas to help protect children from overexposure to UV radiation.

### Strategy 1B Support sun-protective behaviors in outdoor settings

Encouraging Americans to enjoy physical activity in outdoor areas, such as parks, fields, pools, and beaches, is important for physical fitness and health. Just as many recreational areas take steps to reduce the risk of immediate injury from accidents, other outdoor areas can take steps to reduce the short-term risks of sunburn and long-term risks of skin cancer by promoting sun-protective behaviors. Coaches and other organizers of outdoor sports and recreational activities can change the social context by scheduling routine breaks to reapply sunscreen and drink water, which also reduces risk of heat illness.239,250,251,256 Simple modifications to the outdoor environment can help to make sun safety the easy or default choice.

Photo of outdoor shade structure at a park.

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; businesses and employers; early learning centers, schools, colleges, and universities; and community, nonprofit, and faith-based organizations, can support the following efforts:

■ Establish agreements with vendors in outdoor recreation areas to sell sun protection equipment, such as protective hats, clothing, and umbrellas, which will support healthy behaviors and provide additional revenue for communities, businesses, and sports teams.
■ Provide broad spectrum sunscreen with an SPF of 15 or higher in dispensers with prompts and signs that tell people how to apply sunscreen in high-UV areas, such as beaches and pools. Sunscreen should not be the only protection method offered.
■ Provide prompts and signs about sunscreen to remind people to reapply and to encourage users to pair sunscreen with other methods of protection, such as protective clothing and shade.
■ Provide routine breaks during outdoor recreational or occupational activities to reapply sunscreen.

### Strategy 1C Increase availability of sun protection in educational settings

Because many children spend substantial amounts of time in schools and child care and early learning centers, addressing overexposure to UV radiation in these settings is important. Increasing shade in appropriate locations would provide passive protection from overexposure to UV and help protect children from heat illness. Shade audits can help identify where to place trees and shade structures to be most effective. These audits can also be used to identify areas that may already be shaded at key times of the day, so that activities can be located in less UV-intense areas.308,393 CDC's Shade Planning for America's Schools provides guidance and tools for using a shade audit to increase availability and use of shade on school grounds.308

Schools, colleges, and universities can also support sun protection in outdoor recreational settings on campus, such as those used for athletics. Support for sun protection at athletic events has the potential to benefit coaches, athletes, and students, as well as fans and spectators of all ages. Athletes face many of the same risks as outdoor workers.250

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; businesses; early learning centers, schools and school districts, colleges, and universities; community, nonprofit, and faith-based organizations; and individuals and families, can support sun protection in educational settings in the following ways:

■ Conduct shade audits to find solutions that fit a school or child care system's budget, maximize investment, and identify locations where trees and shade structures will be most effective.308
■ Locate activities in shaded areas or schedule activities during low-UV times of day, when feasible.
■ Provide shade trees or structures in key locations identified through audits. Consider public-private partnerships or grants to leverage resources.
■ Include shade planning in the planning of new school facilities.
■ Support sun protection in outdoor athletic settings, especially in high schools, colleges, and universities.

### Strategy 1D Increase availability of sun protection for outdoor workers

Sun protection is of particular importance for outdoor workers, who are at increased risk of skin cancer. Appropriate protection strategies will depend on the occupation and the work site. For example, shade for lifeguards can be relatively inexpensive and practical because they are frequently stationary. For farmworkers, hats and protective clothing are more appropriate. Sunscreen can make a person's hands slippery and may interfere with the work and safety of certain outdoor workers. A readily available hand-washing station to wash hands after reapplying sunscreen can be considered, as well as other methods of protection. Heavy, long-sleeved clothing may also increase risk of heat illness by trapping in heat. Sun protection that takes into account the needs and preferences of workers will likely be most successful.

Corporate risk managers are accustomed to reducing risk for workers, and they may be especially attuned to risks of UV exposure. Providing shade for stationary workers or providing shaded areas for breaks can also reduce the risk of heat illness, but shade alone may not be sufficient, especially in high-UV areas with reflective surfaces, like snow, water, and sand. Employers should consider multiple methods of sun protection for workers.

Key partners in prevention, such as businesses and employers, can protect outdoor workers in the following ways:

■ Provide readily accessible sun protection to all employees, clients, contractors, and other visitors to outdoor work sites, including uniforms or other protective clothing, wide-brimmed hats to protect ears and backs of necks, and sunscreen.
■ Encourage workers to reapply sunscreen throughout their shifts.
■ Modify work environments, when feasible, by increasing the availability of shade and modifying or covering reflective surfaces to reduce workers' UV exposure.
■ Adapt schedules to protect workers from overexposure to UV radiation, when feasible. Employers may be able to schedule outdoor work during times of the day and year when the UV Index is lowest. They may be able to rotate employees through jobs that require significant sun exposure to avoid excessive exposure to individual workers.

## Goal 2 Provide Individuals with the Information They Need to Make Informed, Healthy Choices About UV Exposure

Individuals need clear information that is based on the best and most current evidence to make healthy choices about UV exposure and sun protection. Current skin cancer prevention messages are broad-based and may not resonate with some groups. Most Americans equate sun protection with sunscreen alone, so the importance of other strategies, such as shade and protective clothing, should be emphasized. Messages should also clarify that sunscreen should be used in combination with other protection, and they can emphasize the importance of applying and reapplying ample amounts of sunscreen. Current messages also do not address the need for vitamin D, potentially missing opportunities to highlight the importance of skin cancer prevention in media coverage of vitamin D issues.395

Many Americans lack a general knowledge or awareness about the risks associated with sun exposure.63,243,244 Some groups, especially blacks, the elderly, and people with less education, may perceive themselves to be at low risk of skin cancer.63 However, these groups are at increased risk of being diagnosed with skin cancer at later stages.78,96,245 More comprehensive collection and dissemination of information about skin cancer in the United States would help underscore how frequently these cancers occur.

People need clear information about how to minimize their risk of skin cancer while leading healthy, active lives and enjoying the outdoors. A substantial segment of U.S. adults do not perceive cancer as preventable, and as a result, they may be less likely to engage in skin cancer prevention practices, such as using sunscreen or covering up.246 Lack of understanding of the UV Index is also a barrier to making informed decisions about adequate sun protection while outdoors.247,248 New technologies, such as evidence-based mobile apps that provide information about sun protection directly to individuals, may provide opportunities for direct messaging that is based on an individual's behavior and skin type.371,372 Evidence-based information that is accurate and consistent and provided in various settings is an important part of reducing excessive UV exposure in the U.S. population.

### Strategy 2A Develop effective messages and interventions for specific audiences

Mass media campaigns can be very effective at increasing skin cancer prevention behaviors when they are part of multicomponent, communitywide interventions.396 Before conducting any large messaging campaigns, enhanced understanding of which messages will resonate with specific groups is needed. Because mass media public health campaigns can be expensive, evidence of the cost-effectiveness of different approaches will be valuable. Ensuring that messages and the channels used to disseminate them have been proven to be effective at changing attitudes and behaviors regarding skin cancer prevention in a specific audience is important before making large investments.365,397,398 Effective messaging strategies designed to increase sun protection in various populations, including outdoor workers, specific racial and ethnic groups, younger women, and men across all age groups, are needed.

Photo of two mothers sitting in the shade with their two young children. One mother is applying sunscreen to her child. The other mother is wearing a wide-brimmed hat.

Some research has shown that messages that focus on appearance (such as increased risk of wrinkles and skin aging) can be effective in reducing indoor tanning among college-aged women.278 However, more research is needed to determine the most effective messaging strategies for other demographic groups. Messages should provide specific information on the most effective methods for sun protection applicable for a specific audience, as well as information about the limitations of some types of sun protection. Consistent, clear, and tailored messages with prompts to make specific decisions can encourage people to take the necessary steps to avoid excessive sun exposure when outdoors.230

The UV Index was developed to provide such information, but it is not widely disseminated or understood by the general public.247 Resources like the UV Index need to be promoted more widely through simple messages that include action steps for sun protection, so people understand when and how to take precautions.247,248 Information about the UV Index and the corresponding need for sun protection could be disseminated in the same way as weather forecasts or air quality reports.247 Then, people could routinely consider the UV level just as they consider the weather when they are getting dressed and preparing to go outdoors. Accurate, up-to-date information about UV levels and appropriate protection measures could be provided through a variety of media, such as weather reports, websites, personalized apps for smart phones, and possibly social media.248,372

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; businesses and employers; health care systems, insurers, and clinicians; early learning centers, schools, colleges, and universities; and community, nonprofit, and faith-based organizations, can work together to develop and disseminate messages that accomplish the following:

■ Address the misperception that sunscreen alone is the most effective way to protect skin from the sun.
■ Improve sun protection, especially among adult men. Communications designed to reach men can emphasize the importance of wide-brimmed hats, protective clothing, and broad spectrum sunscreen with an SPF of 15 or higher on exposed areas when outdoors for extended periods.
■ Improve communication in recreational settings. Prompts in outdoor recreational areas and in areas such as locker rooms may improve and normalize the use of sun protection.
■ Improve communication about when and how to use sun protection. Simple messages that include action steps for sun protection could be widely disseminated across a variety of outlets, including weather reports and online tools.
■ Increase understanding about effective use of sunscreens, including what type of sunscreen to use, how much to use, and how often to reapply.
■ Address appearance-related motives and the desire to be tan, especially among young women.
■ Help parents teach their children healthy sun protection behaviors from an early age.

### Strategy 2B Support skin cancer prevention education in schools

Education about skin cancer prevention can be incorporated into school curricula and linked with outdoor activities from an early age, when children are more receptive to such messages. The education sector can be a key partner in supporting healthy choices for sun protection through adolescence and young adulthood. It can also influence the community through connections to families, alumni, and fans.

Educational and behavioral interventions to promote sun protection in child care centers and in elementary and middle schools have been shown to be effective.295 These interventions vary greatly in intensity, duration, and the number of components included. In addition to influencing children's behaviors, these interventions may also influence the practices of adults and caregivers both inside and outside the school.

Key partners in prevention, such as federal, state, tribal, local, and territorial governments and early learning centers and schools, can support sun protection education in the following ways:

■ Implement skin cancer prevention interventions that are designed for and proven to be effective in schools.
■ Adopt lessons from interventions in daily routines, including during recess, physical education, and outdoor extracurricular activities.
■ Adapt proven skin cancer prevention interventions, such as the SunWise program, and disseminate them in child care settings.

### Strategy 2C Integrate sun safety into workplace health education and promotion programs

Skin cancers cause a significant loss of productivity in the U.S. workforce.69,70 Incorporating sun-safety messages into comprehensive workplace health promotion and protection programs can increase health, safety, and productivity and save money. For outdoor workers, interventions designed to increase knowledge about sun protection; activities designed to influence attitudes, behavior, and knowledge of workers; environmental approaches designed to encourage sun protection (such as provision of shade); and policies designed to support sun protection practices have been shown to be effective.306

As an additional benefit, outdoor workers, such as lifeguards, coaches, and ski instructors, may be able to teach and model skin cancer prevention to customers and clients in their workplace.399 Many of these workers have extended interaction with children and are exposed to high levels of UV radiation.

Employers of outdoor workers are required by OSHA to train employees on heat illness prevention. Given the overlap between risk factors for heat illness and risk factors for sunburn and skin cancer, current policies designed to prevent heat illness in the workplace could be adapted to incorporate sun safety. Employees who work in direct sunlight through windows or who drive regularly as part of their job are at risk of overexposure to UVA rays through glass. Sun-safety messages and training are also appropriate for indoor workers. Although indoor workers are not usually exposed to UV radiation during the work day, they may be more likely to have intense, intermittent sun exposure during recreational time on weekends or during vacations, putting them at increased risk of melanoma.

Key partners in prevention from the business sector, including employers, labor representatives, risk managers, and employee wellness program managers, can support sun protection education for workers in the following ways:

■ Incorporate sun-safety information into existing workplace wellness programs. Heat illness prevention programs could be adapted to incorporate sun safety.
■ Provide training to outdoor workers about risks of exposure to UV radiation and the signs and symptoms of overexposure.
■ Encourage outdoor workers, such as lifeguards, coaches, and ski instructors, to be role models and discuss the importance of using appropriate sun protection measures with others.

### Strategy 2D Partner with health care systems and providers to implement and monitor use of recommended preventive services for provider counseling on skin cancer prevention

Currently, the USPSTF recommends provider counseling on skin cancer prevention for fair-skinned youth aged 10–24 years, and these services are generally covered by health insurance.265,277,278 However, skin cancer prevention is one of many competing priorities that health care providers may need to discuss during a medical visit. Providers could be supported to follow USPSTF guidelines in several ways. For example, tools developed and disseminated to providers for behavioral counseling on skin cancer prevention should include appearance-focused messages that have been shown to be effective in reducing the intent to indoor tan. Some of the materials suggested by the USPSTF have already been developed and tested.265

Provider prompts that are part of checklists or EHR systems have been shown to increase provider adherence to guidelines for other topics and may be applicable to skin cancer prevention counseling recommended by the USPSTF.400-402

Key partners in prevention from the health care sector, including health care systems, insurers, and clinicians (such as dermatologists, primary care physicians, physicians' assistants, and nurses), can do the following:

■ Disseminate counseling messages in accordance with USPSTF guidelines.
■ Include specific messages about avoiding indoor tanning when counseling young fair-skinned adolescents and young women, among whom this behavior is common.

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; colleges and universities; health care systems, insurers, and clinicians; and community, nonprofit, and faith-based organizations, can work together on the following:

■ Include provider prompts for counseling to minimize UV exposure for fair-skinned youth aged 10–24 in checklists or EHR systems.
■ Develop and disseminate tools for providers to support behavioral counseling on skin cancer prevention.
■ Collect information on providers' skin cancer prevention counseling practices to help identify further opportunities for intervention and conduct behavioral research to guide and refine tools available for counseling.

### Strategy 2E Establish partnerships between public and private sectors to disseminate effective messages about skin cancer prevention

When paired with other interventions at the community level, communication campaigns can be effective at increasing skin cancer prevention behaviors.295 Partners in prevention can work together across all sectors to provide consistent messages to a wide audience. Dermatologists and dermatologic societies have helped raise public awareness of the issue of skin cancer, and they and the health care sector will continue to be important contributors to these efforts. Media and entertainment industries can also be vital strategic partners in efforts to change social norms related to tanning behaviors. Community, nonprofit, and faith-based organizations can help tailor communications to select populations or geographic areas, directly or through innovative partnerships, such as working with various organizations in the private sector.

To have a broad influence, communication campaigns need to be implemented and sustained over an extended period. A comprehensive approach is needed to ensure that opportunities for sun protection are increased along with communications. Leveraging public-private partnerships may be a cost-effective strategy for such a campaign. Tailored messages about sun protection may be more effective than broad-based messages to the general population.230 Thus, tools that allow for focused messages, such as social and electronic media, can be important for strategic dissemination, especially to some audiences, such as adolescents and young adults.372,379

Evaluations in Australia have shown that efforts to implement a multicomponent, communitywide intervention (SunSmart Australia) were successful in reducing skin cancer rates and were cost-effective.365,397,398 Similar work to implement and evaluate a large-scale, multicomponent, communitywide intervention is needed in the United States.

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; businesses and employers; health care systems, insurers, and clinicians; colleges and universities; community, nonprofit, and faith-based organizations; and individuals and families, can work together in the following ways:

■ Build coalitions to coordinate the efforts of partners across sectors to maximize communication efforts and use consistent messages.
■ Work with media and entertainment industries and the public at large to promote an understanding that tanned skin is not healthy.
■ Leverage public-private partnerships to support and sustain communications campaigns.
■ Explore new technologies for sharing sun protection messages to specific audiences.

### Strategy 2F Enhance ongoing engagement of federal partners to advance our nation's skin cancer prevention efforts

This Call to Action on skin cancer prevention is the result of a collaborative effort across HHS in partnership with other federal departments representing diverse sectors, such as the environment, recreation, occupational health and safety, and trade (see Appendix 5). Using this collective leadership and taking specific actions that align with this Call to Action and with international consensus guidelines will help to advance our nation's skin cancer prevention efforts. Consistent skin cancer prevention messages across federal agencies will also help build consensus behind messaging and streamline the implementation efforts of partners in the skin cancer community.

Many public health and community initiatives overlap with skin cancer prevention, providing opportunities for collaboration. For example, public health messages about physical activity can incorporate sun protection, and sun protection messages can emphasize the importance of regular physical activity and healthy ways to obtain vitamin D. Heat illness campaigns can incorporate sun protection messages as well. Continued interagency coordination is needed to ensure that skin cancer prevention is aligned with other important public health priorities, such as nutrition, physical activity, and obesity prevention.

Partners in prevention in the federal government, such as HHS and its agencies (e.g., CDC, FDA, NIH/NCI), EPA, and OSHA, can work together on the following:

■ Reexamine and update current sun protection messages, ensuring consistency across and within agencies.
■ Identify opportunities to promote and enhance cross-agency and departmental collaborations to plan, implement, and disseminate skin prevention messages and activities.

## Goal 3 Promote Policies that Advance the National Goal of Preventing Skin Cancer

Efforts to change social norms and increase knowledge about UV exposure are effective if they are supported by policies that promote healthy behaviors. Policies can establish support for sun protection from officials, managers, and employees, and they can be used to set priorities for resource allocation and to promote institutional changes that lead to increased sun protection. For this reason, policies and procedures in schools, health care facilities, communities, and workplaces and at state and national levels can have a significant effect on the success or failure of other skin cancer prevention efforts. Policies should also be routinely evaluated to assess their effectiveness, compliance, enforcement, and feasibility, especially if resources change. Skin cancer prevention is one of many other important concerns, and it should be considered in tandem with policies designed to address other health priorities, such as nutrition, physical activity, and obesity prevention.

### Strategy 3A Support inclusion of sun protection in school policies, construction of school facilities, and school curricula

Rather than relying on individual schools to incorporate sun protection policies and education, states and school districts can support incorporation of sun-safety education in the required curriculum, as in Arizona and Florida.303,325 Such policies will be most effective if they are accompanied by input from, and professional development for, teachers or other school staff who are delivering the sun-safety curriculum.403 Some school policies can create barriers to sun protection by prohibiting or limiting the use of sunscreen or hats and sunglasses.300 These barriers can be addressed through policies that specifically allow or encourage students to wear hats, protective clothing, and sunscreen during outdoor activities. School, school district, and state policies can also encourage the use and planning of shade structures and could include requirements that school activities be scheduled in areas with more shade and at less UV-intense times of day. In addition, schools and school districts can take UV exposure into consideration when new play structures, school buildings, or child care and early learning centers are being planned as a way to ensure that shaded areas are provided for outdoor activities.

Parents are influential members of school communities, and they can work with local schools, school boards, and school administrations to make sure that appropriate, well-designed shade is considered when new schools are planned and that older schools are retrofitted. Parents and parent organizations may also be able to influence school policies on children's personal use of sunscreen, hats, and clothing while at school; on use of the UV Index to make decisions about outdoor activities; and on the inclusion of skin cancer prevention in health or science curricula.

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; early learning centers, schools and school districts, colleges, and universities; community, nonprofit, and faith-based organizations; and individuals and families, can do the following:

■ Incorporate sun-safety education into required school curriculum at the district or state level.
■ Address barriers to sun protection in schools.
■ Encourage the use of shade through shade-planning policies.
■ Involve parents and parent groups in the development and promotion of skin cancer prevention policies in schools.

### Strategy 3B Promote electronic reporting of reportable skin cancers and encourage health care systems and providers to use such systems

Health care providers who diagnose or treat melanomas (both in situ and invasive) are required to report cases to a central cancer registry in all 50 states and the District of Columbia. Although hospitals generally have reporting systems established, many providers in private practice who diagnose skin cancers, including dermatologists and primary care doctors, are unaware of requirements to report melanomas or are unsure of how to report to their state or local registry.384,385 Additional steps to increase awareness among providers and to make it easier for providers to report this information are likely to increase reporting. Implementation of EHR systems for data collection can help increase reporting through incentives provided by CMS. In addition, electronic reporting directly from pathology laboratories to a central cancer registry has been increasing, and this practice significantly improves capture of melanoma cases.404 Automation of reporting and other improvements in health information systems may increase ease and convenience of reporting.

Large national organizations, such as the American Academy of Dermatology, can help to educate health care providers about mandatory reporting requirements in their states. First steps can include compiling state-level reporting procedures in an easy-to-reference format and then disseminating these to providers through affiliated state health care provider organizations and continuing medical education programs.

Key partners in prevention, such as federal, state, tribal, and territorial governments and health care systems, provider organizations, insurers, and clinicians, can do the following:

■ Increase awareness of reporting requirements, especially among primary care doctors and dermatologists in private practice.
■ Provide clear guidance and specific action steps for reporting melanomas.
■ Adhere to policies that require reporting of melanomas (both in situ and invasive).

### Strategy 3C Incorporate sun safety into workplace policies and safety trainings

Employer policies can substantially reduce harms from overexposure to UV in the workplace for employees, contractors, clients, and other visitors to the work site by ensuring that strategies for reducing UV exposure among workers are consistently and fairly applied. Workers or their representatives should be involved in any decisions about policies that incorporate sun protection to ensure that these policies are functional and effective. Sun protection policies that take into account the job tasks and other safety and health risks will be the most useful. Employers who encourage behavioral changes and communicate well with their workers will increase the success and adoption of new policies.

Employers should also consider policies to reduce UV exposure from other environmental factors, such as reflective surfaces or the use or presence of substances that increase sensitivity to UV radiation, such as certain tars, dyes, or pesticides.405 Policies that call for work to be scheduled at times of day or year that are less UV-intense can reduce exposure. In addition, outdoor workers are not the only ones at risk of excessive UV exposure on the job. Workers in certain occupations, such as drivers, may encounter substantial UV exposure through windows and may also be at increased risk. Sun protection policies for these workers can include provision of equipment or modifications to glass in windows.406

Key partners in prevention in federal, state, tribal, local, and territorial governments and in the business sector, such as employers, labor representatives, and risk managers, can enact policies that accomplish the following:

■ Support provision of sun protection clothing and equipment for workers, such as long-sleeved shirts and long pants; hats that shade the face, ears, and back of the neck; and broad spectrum sunscreen with an SPF of 15 or higher.
■ Modify the work environment where feasible to minimize UV exposure.
■ Take into account UV levels when scheduling work hours when feasible.
■ Encourage the rotation of workers in UV-intense positions to reduce UV exposure to individual employees.

### Strategy 3D Support shade planning in land use development

Strategic shade planning can maximize the amount of shade provided to key areas of activity during the times of the day and months of the year with the highest UV levels. If placement and materials of shade structures are not carefully considered, shade may not provide sufficient protection, or the structures may not provide shade to the intended space during times when UV radiation is most intense because the angle of the sun varies throughout the day and year. In addition, shade needs to complement the way an outdoor space is used. For example, a shade structure with a low roof built on an area used to play volleyball or a tree planted in the middle of a space used to play soccer or kickball is clearly incompatible with the intended use of the space.

State or federal decision makers could support efforts to plan and build effective shade structures in communities, taking into account local needs for shade and recreational areas. One model is the Safe Routes to Schools program (http://www.saferoutesinfo.org/), which provides grants to schools and school districts from federal transportation funding. Any program used should be evaluated to ensure that the funding is effective in reducing key adverse outcomes.

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; businesses and employers; early learning centers, schools, colleges, and universities; community, nonprofit, and faith-based organizations; and individuals and families, can do the following:

■ Support shade planning in the overall process of designing and building new outdoor public spaces, such as parks, playgrounds, and schools.
■ Implement policies to support increased provision of shade structures in local communities.

## Goal 4 Reduce Harms from Indoor Tanning

Indoor tanning devices, classified by WHO in 2009 as a known human carcinogen, expose the skin to intense levels of UV radiation. As discussed in the “Reducing the Risks of Skin Cancer” section, indoor tanning is of strong concern because it has been estimated to be related to more than 400,000 cases of skin cancer in the United States each year: 245,000 BCCs, 168,000 SCCs, and 6,000 melanomas.124 In addition to increasing skin cancer risk, indoor tanning can cause burns to the skin, acute and chronic eye diseases if eye protection is not used, and, if tanning devices are not properly sanitized, skin infections.139-141 About one out of every three non-Hispanic white women aged 16–25 years stated that they had tanned in the past 12 months, and many said they do so frequently.134

Unlike sun exposure, indoor tanning provides concentrated UV exposure regardless of geographical location, time of year, or time of day. Indoor tanning also exposes areas of the body not normally exposed to intense UV radiation, further increasing risk.115 However, indoor tanning can be completely avoided, which allows for points of intervention beyond those used to reduce sun exposure.

### Strategy 4A Monitor indoor tanning attitudes, beliefs, and behaviors in the U.S. population, especially among indoor tanners, youth, and parents

Increased data on attitudes and beliefs about indoor tanning would help guide the development of policies, tailored messages, and programs for indoor tanning prevention and cessation. Improved understanding of indoor tanners' motivations, especially subgroups that have been studied less frequently, such as males or nonwhite tanners, can help guide the development of messages and policies to address tanning. Monitoring the attitudes and beliefs of parents and their children is particularly important as part of efforts to reduce indoor tanning among minors, given parental influence on youth tanning behaviors. Monitoring attitudes and beliefs can also provide information on the effect of indoor tanning policies on attitudes and social norms.

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; health care systems, insurers, and clinicians; colleges and universities; and nonprofit organizations that conduct science, can support efforts to do the following:

■ Examine motivations for indoor tanning among frequent and event tanners, and examine motivations for not tanning among never-tanners.
■ Examine children's and parents' attitudes and beliefs about indoor tanning.
■ Conduct research to better quantify the effect of indoor tanning legislation on attitudes, behavior, and social norms.

### Strategy 4B Continue to develop, disseminate, and evaluate tailored messages to reduce indoor tanning among populations at high risk

Conflicting messages to the public from industry and health agencies cause confusion about the risks of indoor tanning. Research shows that appearance-based messaging and behavioral counseling appear to be effective in reducing tanning behaviors among college-aged women.263-266 This strategy has not been tested in other populations of indoor tanners. Messages that focus on the prevalence of an unhealthy behavior may unintentionally normalize or reinforce the behavior.407 For this reason, messages to reduce indoor tanning may be most effective if they emphasize that most young women do not indoor tan but instead choose to embrace their natural skin color.279 This strategy also needs to be tested. Although teens and young adult women are most likely to engage in indoor tanning, other populations also indoor tan. Having a mother who tans is a strong predictor of adolescent girls' initiation of tanning, so understanding how to present messages to mothers is also important.408

Outcomes of effective messaging interventions to reduce indoor tanning should be evaluated in order to provide information on unintended consequences, such as increased tanning outdoors. Messaging strategies may vary for different populations of indoor tanners. People who have accumulated UV exposure from indoor tanning or sunbathing are at increased risk of skin cancer, and messages focusing on the importance of awareness and early detection of potentially malignant lesions may be appropriate.

Photo of three high school aged girls with different natural skin tones wearing sunglasses and laughing as they walk down the street.

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; health care systems, insurers, and clinicians; colleges and universities; and nonprofit organizations that conduct science, can do the following:

■ Develop and test messages for populations at high risk, including current tanners and those most likely to initiate indoor tanning.
■ Develop and test messages for parents.
■ Evaluate the long-term effects that messages have on intentional tanning behaviors, both indoor and outdoor.

### Strategy 4C Support organizational policies that discourage indoor tanning by adolescents and young adults

Colleges and universities sometimes have agreements with tanning salons that allow students to use university-sponsored debit cards to pay for tanning services.409 Many colleges and universities have adopted campus polices that discourage alcohol and tobacco use, and similar types of policies could address indoor tanning. Colleges and universities could examine and address the financial incentives, campus policies, systems, and social norms that directly or indirectly encourage indoor tanning in order to create an educational environment that is supportive of student health and well-being. Reducing availability of tanning services on campus could lead to reduced use of indoor tanning by students and to changes in social norms related to tanning.

Key partners in prevention in the education sector, especially high schools, colleges, and universities, can address indoor tanning on campus in the following ways:

■ Adopt campus policies that discourage indoor tanning by their students on campus.
■ Reconsider campus practices that may encourage indoor tanning, such as the use of school-sponsored debit cards; financial arrangements between student organizations and members of the indoor tanning industry; and on-campus advertising, incentives, and promotional materials for indoor tanning.
■ Develop an action plan to promote campuswide UV protection strategies.

### Strategy 4D Enforce existing indoor tanning laws and consider adopting additional restrictions

The younger the age of indoor tanning initiation, the more the risk increases.114,116,118,119 WHO classifies tanning beds as Class I human carcinogens and recommends that they never be used by anyone younger than age 18 years.27 Australia and most western European countries currently prohibit indoor tanning among minors.328,369 Currently, at least 44 states and the District of Columbia have some kind of law or regulation related to indoor tanning,329-334 including bans on indoor tanning for minors under a certain age, ranging from 14 to 18; laws requiring parental accompaniment or parental permission; or regulations that otherwise reduce harms (such as requiring eye protection). FDA now requires that indoor tanning devices carry a visible black box warning on the device that explicitly states that the sunlamp product should not be used on people younger than age 18 years.349

In many locations, such as gyms and apartment complexes, indoor tanning devices are available for use without the supervision of a trained operator. Although FDA regulations do not distinguish between tanning devices used in supervised and unsupervised settings, unsupervised tanning devices are often not held to the same industry standards as indoor tanning salons, which may be licensed by the state or which may commit to certain standards as members of indoor tanning associations.

The inherent risks of indoor tanning are high, but unsupervised tanning locations provide none of the consumer protection mechanisms created by states and the indoor tanning industry to reduce risks of acute harm to consumers. The availability of unsupervised use may also limit the effect of efforts to reduce indoor tanning among minors because of difficulty enforcing current or future regulations.

Key partners in prevention in the government sector, such as federal, state, tribal, local, and territorial governments, can do the following:

■ Ensure that facilities operate indoor tanning devices in compliance with established health and safety regulations.
■ Adopt evidence-based policies such as age restrictions for minors.
■ Investigate and address specific allegations of deceptive advertising by indoor tanning salons.
■ Support efforts to implement and disseminate effective training programs for operators of indoor tanning devices.
■ Educate consumers on FDA warnings and contraindications for indoor tanning device use.

Industry groups could also help to reduce the harms of indoor tanning in the following ways:

■ Ensure compliance with laws that discourage deceptive and misleading advertisement.
■ Increase communication to consumers on the risks of indoor tanning.
■ Ensure compliance with federal and state regulations (such as UV exposure guidelines, training documentation, and warning labels).

### Strategy 4E Address the risks of indoor tanning with improved warning labels and updated performance standards

Current warning labels are often not easily visible to customers, or they may be disregarded.341,410 Public health messages should directly address competing health claims from advertising and should be clear that risks of indoor tanning are substantially higher than limited sun exposure. Strengthening efforts to communicate the risks of indoor tanning to consumers at the point of use may be an effective strategy. Stronger warning labels, visible to consumers and with information describing the risks of indoor tanning, combined with other outlets of communication about the risks of indoor tanning, could help make consumers aware of the danger and change perceptions about intense exposure to UV radiation.352,411

Manufacturers of indoor tanning devices (also known as sunlamp products) currently are required to certify that their products comply with the FDA Performance Standard for Sunlamp Products (21 CFR 1040.20).348 FDA is working to reflect current science on the risks of indoor tanning, improve the visibility and readability of the warning label, and update and promote compliance with the performance standard.

As part of FDA's recent reclassification of indoor tanning devices to Class II medical devices (moderate to high risk), manufacturers will be required to do the following:

■ Include a visible black box warning on the device that people younger than age 18 years should not use these devices.
■ Receive premarket notification 510(k) clearance from FDA for newly marketed devices (which were previously exempt from any premarket review).
■ Show that their products have met certain performance testing requirements.
■ Address certain product design characteristics.
■ Provide comprehensive labeling that presents consumers with clear information on the risks of use.349,350

Key partners in prevention in the government sector, such as federal, state, tribal, local, and territorial governments, can do the following:

■ Require indoor tanning locations to prominently display the health warnings about indoor tanning in their facilities and provide verbal and written explanations of health risks to customers.
■ Test different messages for warnings and signs to determine how to most accurately convey risk to consumers.
■ Update performance standards for indoor tanning devices to reflect current science.

## Goal 5 Strengthen Research, Surveillance, Monitoring, and Evaluation Related to Skin Cancer Prevention

This Call to Action proposes both the expansion of existing strategies and the creation of new strategies for skin cancer prevention in the United States. As with all public health initiatives, continuing to build on existing research and surveillance activities is critical to future success in reducing the incidence of skin cancer. As these strategies are implemented, skin cancer incidence and death rates, as well as trends in risk behaviors related to skin cancer, will need to be monitored.

Monitoring and evaluation of interventions will allow researchers to learn from the process of implementation, address weaknesses quickly, track progress over time, and ultimately determine the success of interventions in changing behavior and preventing disease, as well as their cost-effectiveness. Federal, state, and local public health agencies, nonprofit organizations, and academic researchers can work together to conduct this important research and guide future interventions.

Photo of a grandfather and his grandson in a park wearing wide-brimmed hats.

### Strategy 5A Enhance understanding of the burden of skin cancer and its relationship with UV radiation

More information is needed on the epidemiology and risk factors for skin cancer and the risks of different levels of UV exposure. Epidemiologic studies of skin cancers are limited by underreporting of early-stage melanomas. Increased reporting of melanomas will improve surveillance of melanoma incidence rates. Overdiagnosis of early-stage lesions has also been raised as an issue affecting epidemiologic studies, and this problem is suspected because incidence rates have increased disproportionately to death rates. Better understanding of the natural history of melanoma would help improve accuracy of diagnoses and therefore surveillance. More information on patient history of UV exposure and behavior can help identify those at risk and provide data on risk factors and prevention.

Photo of a family playing soccer in their shaded backyard.

Lack of national surveillance of BCC and SCC presents another barrier to measuring the burden of skin cancer, which also inhibits the ability to measure outcomes of interventions. Data on these cancers can potentially be collected through EHRs as part of sentinel systems in limited areas. Also, more information is needed to determine the effectiveness of screening among the general population, as well as the relative benefits and cost benefits of various screening strategies, particularly in a diverse population like that of the United States, where wide variations exist in environmental UV exposure and the geographic latitude (and thus the UV intensity) of where people live.

Although national surveillance of these cancers is not feasible, large health care systems or other entities could use EHRs to establish systems for collecting their own data. Modeling studies could be used to better estimate trends in the incidence of BCC and SCC. Economic analyses could be used to quantify the costs of melanoma, BCC, and SCC. These types of analyses can incorporate both direct and indirect economic costs, as well as human costs.

Key partners in prevention, such as federal, state, tribal, local, and territorial governments; health care systems, insurers, and clinicians; colleges and universities; and nonprofit organizations that conduct scientific research, can do the following:

■ Enhance understanding of the burden of skin cancer, including incidence and death rates from melanoma, BCC, and SCC.
■ Continue to monitor the effects of UV exposure on human health.
■ Conduct economic analyses to quantify the effects on disease and death rates, productivity, and health care costs.
■ Increase research efforts to determine population groups most likely to benefit from skin cancer screening and early detection and potential effects on mortality, especially for populations at high risk.

### Strategy 5B Evaluate the effect of interventions and policies on behavioral and health outcomes

Although sufficient evidence exists to take action to prevent skin cancer, evaluating the immediate, intermediate, and long-term effects of skin cancer prevention policies and interventions remains critical to their success. Evaluations should examine changes in sun protection behavior and whether they are sustained over time, as well as the effect of interventions on incidence of sunburn over time and on more distant outcomes, such as skin cancer incidence. Ongoing monitoring and periodic evaluation provide the opportunity to learn from and improve on existing interventions and policies and adjust if necessary.

Future interventions and policies should strive to include an impact evaluation component, whenever feasible. Evaluations can help employers set priorities and allocate resources toward sun protection strategies that work. Employee education interventions can be evaluated for efficacy across cultures and languages to address the diversity of the workforce.

Key partners in prevention, such as public health agencies, colleges and universities, and nonprofit organizations that conduct scientific research, can evaluate interventions in the following ways:

■ Examine the duration of the effects of interventions in child care and early learning centers and elementary and middle schools on sun protection behaviors and sunburn later in life.
■ Continue to evaluate the effectiveness of sun protection interventions in high school, college, and university settings as evidence evolves.
■ Evaluate whether clinicians follow current USPSTF recommendations on counseling for sun protection among fair-skinned youth aged 10–24 years.
■ Determine the health effects and cost-effectiveness of efforts to promote sun protection among outdoor workers.
■ Evaluate the effects of communitywide shade policies.
■ Measure the effect of communication interventions on attitudes and behaviors.

### Strategy 5C Build on behavioral research and surveillance related to UV exposure

Ongoing surveillance of sun protection behaviors and general outdoor UV exposure in national surveys would help to measure progress over time and provide direction for future interventions. To fully understand how best to support the prevention of excessive outdoor sun exposure, more information is needed on how much (or how little) outdoor UV exposure the U.S. population in general and subpopulations specifically are receiving.

More in-depth behavioral research is needed in addition to surveillance. Many interventions to date have used a multicomponent approach that combines strategies directed at individuals, mass media campaigns, and environmental and policy changes. Research is needed to determine the contribution of individual components to the observed behavior change. Determining which components within multicomponent interventions are critical to eliciting behavior change would help prioritize and maximize use of limited resources. Current evidence suggests that age restrictions may be more effective than parental permission and accompaniment laws at reducing indoor tanning among minors,335 but more evidence is needed.

States could consider including a question on indoor tanning frequency on their YRBS questionnaire, which would allow for state-level estimates of the prevalence of indoor tanning among high school students. Similarly, a question on indoor tanning frequency could be added to surveys such as the BRFSS to monitor indoor tanning in adults. If states begin collecting data on indoor tanning, they can track changes in indoor tanning behaviors over time as new policies are implemented. Survey findings can provide evidence on the effectiveness of indoor tanning policies and can guide future policy decisions at state and national levels.

Key partners in prevention, such as public health agencies, colleges and universities, and nonprofit organizations that conduct scientific research, can expand upon current research in the following ways:

■ Increase understanding of indoor tanning behaviors, including when, where, and how people tan.
■ Increase understanding of motivations to tan or not to tan.
■ Strengthen collection of information on indoor tanning on national surveys, such as the state YRBS and the national and state BRFSS.
■ Monitor changes in indoor tanning behaviors and social norms over time to evaluate the effectiveness of legislation or regulations to reduce intentional tanning, as well as to guide future efforts.
■ Collect and examine information on outdoor tanning to monitor unintended consequences of indoor tanning restrictions.
■ Collect and examine information on average outdoor UV exposure in the U.S. population.

### Strategy 5D Quantify the prevalence of tanning in unsupervised locations

Currently, little is known about the prevalence of, access to, and attitudes toward unsupervised tanning devices. The availability of these devices creates a barrier to successful implementation of indoor tanning controls and limits the effect of efforts designed to protect minors from the harms of indoor tanning. Efforts are needed to quantify how many tanning devices are available for use outside of tanning salons (such as in gyms, apartment complexes, or beauty salons), where they are located, who has access to them, and whether they are being used in accordance with FDA performance standards. Similarly, more information is needed about the prevalence of home ownership of an indoor tanning device and the standards of devices found in homes.

Key partners in prevention, such as public health agencies, colleges and universities, and nonprofit organizations that conduct scientific research, can do the following:

■ Quantify the prevalence of indoor tanning device use in unsupervised locations.
■ Describe patterns of use of unsupervised tanning devices.
■ Provide information about indoor tanning device use in private settings, such as homes.
■ Quantify the health effects of unsupervised indoor tanning device use.