# Abbreviations and Acronyms

25OHD: 25-hydroxyvitamin D
AHRQ: Agency for Healthcare Research and Quality
BCC: basal cell carcinoma
BRFSS: Behavioral Risk Factor Surveillance System
CCC: Comprehensive Cancer Control
CDC: Centers for Disease Control and Prevention
CMS: Centers for Medicare & Medicaid Services
DHA: dihydroxyacetone
EHR: electronic health record
EPA: U.S. Environmental Protection Agency
FDA: U.S. Food and Drug Administration
FTC: Federal Trade Commission
HHS: U.S. Department of Health and Human Services
HINTS: Health Information National Trends Survey
IARC: International Agency for Research on Cancer
IOM: Institute of Medicine
ITA: Indoor Tanning Association
NCCCP: National Comprehensive Cancer Control Program
NCI: National Cancer Institute
NHANES: National Health and Nutrition Examination Survey
NHIS: National Health Interview Survey
NIH: National Institutes of Health
NMSC: nonmelanoma skin cancer
NPS: National Park Service
OSHA: Occupational Safety and Health Administration
P.L.A.N.E.T.: Plan, Link, Act, Network with Evidence-based Tools
RAYS: Raising Awareness in Youth About Sun Safety
RTIPs: Research-tested Intervention Programs
SAD: seasonal affective disorder
SAMHSA: Substance Abuse and Mental Health Services Administration
SCC: squamous cell carcinoma
SES: socioeconomic status
SHPPS: School Health Policies and Practices Study
SPF: sun protection factor
USPSTF: U.S. Preventive Services Task Force
UV: ultraviolet
UVA: ultraviolet A
UVB: ultraviolet B
UVC: ultraviolet C
WHO: World Health Organization
YRBS: Youth Risk Behavior Survey