# Federal Departments, Agencies, and Policies

Appendix 5 presents information about current federal efforts on skin cancer prevention. Recommendations from federal agencies and from national organizations that are leaders in skin cancer prevention are summarized in Table A on page 79.

Table A Skin Cancer Prevention Recommendations by Federal Agencies and National Organizations

Agency | Recommendations
FEDERAL AGENCIES
Centers for Disease Control and Prevention http://www.cdc.gov/cancer/skin/basic_info/prevention.htm | - Stay in the shade, especially during midday hours.; - Wear clothing that covers your arms and legs.; - Wear a hat with a wide brim to shade your face, head, ears, and neck.; - Wear sunglasses that wrap around and block both UVA and UVB rays.; - Use sunscreen with sun protection factor (SPF) 15 or higher and both UVA and UVB protection.; - Avoid indoor tanning.
U.S. Environmental Protection Agency http://www.epa.gov/sunwise/actionsteps.html | - Do not burn.; - Avoid sun tanning and tanning beds.; - Generously apply sunscreen.; - Wear protective clothing.; - Seek shade.; - Use extra caution near water, snow, and sand.; - Check the UV Index.; - Get vitamin D safely.
U.S. Food and Drug Administration http://www.fda.gov/ForConsumers/ConsumerUpdates/ucm049090.htm | - Reduce time in the sun.; - Dress with care.; - Be serious about sunscreen.; - Tips for applying sunscreen.; - Protect the eyes.; - Slip! Slop! Slap! Wrap!
Occupational Safety and Health Administration https://www.osha.gov/Publications/OSHA3166/osha3166.html | - Cover up.; - Use sunscreen.; - Wear a hat.; - Wear UV-absorbent shades.; - Limit exposure.
NATIONAL ORGANIZATIONS
American Academy of Dermatology http://www.aad.org/spot-skin-cancer/understanding-skin-cancer/how-do-i-prevent-skin-cancer | - Seek shade when appropriate.; - Wear protective clothing.; - Generously apply a broad spectrum, water-resistant sunscreen.; - Use extra caution near water, snow, and sand.; - Avoid tanning beds.
American Academy of Pediatrics http://www.healthychildren.org/english/safety-prevention/at-play/pages/Sun-Safety.aspx | - Keep babies younger than 6 months out of direct sunlight. Find shade under a tree, umbrella, or the stroller canopy.; - When possible, dress yourself and your kids in cool, comfortable clothing that covers the body, like lightweight cotton pants, long-sleeved shirts, and hats.; - Select clothes made with a tight weave—they protect better than clothes with a looser weave.; - Wear a hat or cap with a brim that faces forward to shield the face.; - Limit your sun exposure between 10 am and 4 pm, when UV rays are strongest.; - Wear sunglasses with at least 99% UV protection (look for child-sized sunglasses with UV protection for your child).; - Use sunscreen.; - Set a good example.
American Cancer Society http://www.cancer.org/cancer/skincancer-melanoma/moreinformation/skincancerpreventionandearlydetection/skin-cancer-prevention-and-early-detection-u-v-protection | - Slip! Slop! Slap! Wrap!; ■ Slip on a shirt.; ■ Slop on sunscreen.; ■ Slap on a hat.; ■ Wrap on sunglasses to protect the eyes and skin around them.; - Seek shade.; - Protect your skin with clothing.; - Read the labels.; - Be sure to apply sunscreen properly.; - Wear a hat.; - Wear sunglasses that block UV rays.; - Avoid tanning beds and sunlamps.; - Protect children from the sun.
National Council on Skin Cancer Prevention http://www.skincancerprevention.org/skin-cancer/prevention-tips | - Do not burn or tan.; - Seek shade.; - Wear protective clothing.; - Generously apply sunscreen.; - Use extra caution near water, snow, and sand.; - Get vitamin D safely.

## U.S. Department of Health and Human Services: Healthy People

The U.S. Department of Health and Human Services (HHS) and federal agencies within HHS—including the Centers for Disease Control and Prevention (CDC), National Cancer Institute (NCI) within the National Institutes of Health (NIH), U.S. Food and Drug Administration (FDA), and others—work together to develop Healthy People goals and objectives, which provide science-based, 10-year national objectives for improving the health of all Americans. Measureable objectives related to skin cancer include reducing melanoma mortality, reducing the proportion of adults who report sunburn, reducing the proportion of adults and high school students in grades 9–12 who report using artificial sources of UV light for tanning, and increasing the proportion of adults and high school students in grades 9–12 who follow protective measures that may lessen the risk of skin cancer.

CDC and NCI work together in ongoing efforts to monitor skin cancer and behaviors related to known risks and to track progress toward meeting the Healthy People objectives for skin cancer. For example, in November 2011, several articles from CDC were published in a supplemental issue of the Journal of the American Academy of Dermatology (http://www.jaad.org/issues?issue_key=S0190-9622%2811%29X0013-0). Some articles described patterns of melanoma, and others focused on melanoma prevention. Contributors included partners from the state-based central cancer registries, the American Cancer Society, NCI, and academic centers.

In addition, CDC and NCI routinely publish analyses of data from the National Health Interview Survey and its Cancer Control Supplement (NHIS CCS),133,227 which they cosponsor. CDC also publishes analyses of Youth Risk Behavior Survey (YRBS) data related to both sun protection and indoor tanning.134,423

## National Cancer Institute

NCI produces the Cancer Trends Progress Report Updates (http://progressreport.cancer.gov), which summarize the nation's progress against skin cancer and other cancers in relation to Healthy People objectives and other targets set by HHS. The first report was published in 2001, and the data have been updated about every 2 years since then, with annual updates beginning in 2014. The updates include key measures of progress along the cancer control continuum, including risk factor monitoring for skin cancer, especially related to sun protection behavior, indoor tanning, and sunburn. They use national trend data to illustrate where advances have been made and gaps still remain.

NCI also fields the Health Information National Trends Survey (HINTS), which collects nationally representative data about the American public's use of cancer-related information.246 For example, HINTS publications show that, despite the large control over behavioral factors that people may exert—such as avoiding UV exposure, wearing protective clothing, and applying broad spectrum sunscreen with a sun protection factor (SPF) of 15 or higher—many adults do not perceive cancer as preventable and are less likely to engage in skin cancer prevention practices.244

NCI's Cancer Control P.L.A.N.E.T. (Plan, Link, Act, Network with Evidence-based Tools) (http://cancercontrolplanet.cancer.gov) is a web-based portal that provides access to data and resources for cancer control planning efforts. It is a joint effort between NCI, CDC, the Substance Abuse and Mental Health Services Administration (SAMHSA), and the Agency for Healthcare Research and Quality (AHRQ). The portal can help planners, program staff, and researchers to design, implement, and evaluate evidence-based cancer control programs. State-level melanoma incidence and mortality data and data on skin cancer risk perceptions are also available on the site through State Cancer Profiles (http://statecancerprofiles.cancer.gov).

NCI and SAMHSA cosponsor the Research-tested Intervention Programs (RTIPs) website (http://rtips.cancer.gov/rtips), which is a searchable database of cancer control interventions and related program materials. Interventions included in the RTIPs database must meet specific inclusion criteria to ensure research integrity, intervention impact, and amenability to dissemination in the United States. When possible, the RTIPs page for a given intervention links directly to corresponding recommendations from The Guide to Community Preventive Services (The Community Guide) (see Table B on page 81 and http://www.thecommunityguide.org/cancer/index.html). The website is designed to provide program planners and public health practitioners easy and immediate access to research-tested materials for use in a community or clinical setting.

Table B Community-Level Approaches to Preventing Skin Cancer: Recommendations from The Guide to Community Preventive Services

Setting | Target Audience | Intervention Components | Task Force Findings
EDUCATION AND POLICY INTERVENTION STRATEGIES
Child care centers | Children, caregivers (staff, teachers, or parents), or both | Include one or more of the following:; - Educational activities through classroom instruction.; - Small media, such as brochures and flyers.; - Activities to influence children's or students' behaviors, such as modeling, demonstration, or role-playing.; - Activities to change the knowledge, attitudes, or behaviors of parents, caregivers, or teachers.; - Environmental changes, such as making shaded areas available for outdoor activities.; - Policy changes, such as scheduling outdoor activities to avoid hours of peak sunlight or allowing students to wear protective hats when outdoors. | Recommended based on evidence of effectiveness in increasing children's protection from excessive UV exposure (May 2013).
Primary and middle schools (kindergarten through 8th grade) | Children, caregivers (staff, teachers, or parents), or both | | Recommended based on evidence of effectiveness in increasing children's sun protection behaviors and decreasing UV exposure, sunburn incidence, and formation of new moles (August 2012).
High schools and colleges | Adolescents and young adults, teachers, or parents or a combination of the three | | Insufficient evidence (May 2013).
Health care settings | Providers, patients, or clients | Include one or more of the following:; - Provider education sessions.; - Internet-based education.; - Videos.; - Role-modeling. | Insufficient evidence (July 2002).
Outdoor recreational and tourism settings | Recreation staff, adults, and children | Include one or more of the following:; - Educational brochures.; - Sun-safety training for recreation staff.; - Role-modeling by recreation staff.; - Sun-safety lessons.; - Interactive activities.; - Signs or other prompts encouraging use of sun protection. | Recommended based on strong evidence of effectiveness in improving sunscreen use and improving participants' sun protective behaviors. (February 2014).
Outdoor occupational settings | Workers | Include one or more of the following:; - Provision of information to workers through instruction, small media, or both.; - Additional activities intended to change the knowledge, attitudes, beliefs, intentions, or behaviors of workers, such as modeling or demonstrations.; - Environmental or policy approaches, such as providing shade and sunscreen. | Recommended based on evidence of effectiveness in increasing outdoor workers' sun protective behaviors and in reducing sunburn (August 2013).
COMMUNITYWIDE INTERVENTION STRATEGIES
Multicomponent, communitywide interventions | Communitywide in a defined geographic area | A combination of the following across multiple settings:; - Individual-directed strategies.; - Mass media campaigns.; - Environmental and policy changes. | Recommended based on evidence of effectiveness in increasing sunscreen use (April 2012).
Mass media campaigns (when implemented alone rather than as part of a multicomponent intervention) | Communitywide, but may be aimed at specific audiences; typically uses broad distribution channels | Dissemination of information and behavioral guidance to wide audiences through media channels such as the following:; - Print media (e.g., newspapers, magazines).; - Broadcast media (e.g., radio, television).; - Billboards.; - Internet. | Insufficient evidence (June 2011).
INTERVENTION STRATEGIES TARGETING CHILDREN'S PARENTS AND CAREGIVERS
Strategies targeting children's parents and caregivers | Children's parents and caregivers (e.g., nannies, other family members, lifeguards, teachers, coaches) | Single or multicomponent interventions, including one or more of the following:; - Educational component using small media (e.g., educational brochures, newsletters, tip cards, postcard reminders), sun-safety lessons, interactive activities, and incentives for parents and children.; - Environmental component (e.g., an increase in available shaded areas, free sunscreen, point-of-purchase prompts and discount coupons for hats, sun-safety logo T-shirts, sunscreen). | Insufficient evidence (July 2002).

Source: The Guide to Community Preventive Services (http://www.thecommunityguide.org/cancer/skin/education-policy/index.html).

NCI scientists also have developed an online Melanoma Risk Assessment Tool, which is designed to help clinicians to evaluate an individual's risk of melanoma (http://www.cancer.gov/melanomarisktool/). The tool is limited to estimating risk for non-Hispanic whites, and it is not appropriate for people with a family history of melanoma.

NCI's Physician Data Query (PDQ) is a comprehensive cancer database that contains summaries on a wide range of cancer topics. The PDQ cancer information summary on skin cancer provides health professionals with comprehensive, peer-reviewed, evidence-based information about skin cancer prevention. It is intended as a resource to inform and assist clinicians; it does not provide practice guidelines. See http://www.cancer.gov/cancertopics/pdq/prevention/skin/HealthProfessional.

In addition, the NCI website has health education information on skin cancer causes, prevention, and treatment (http://www.cancer.gov/cancertopics/types/skin). It includes a unique resource for people with darker skin, called Anyone Can Get Skin Cancer (http://www.cancer.gov/cancertopics/prevention/skin/anyone-can-get-skin-cancer). NCI also sponsors extramural research related to health behaviors, including skin cancer prevention.424

## Centers for Disease Control and Prevention

CDC provides administrative, research, and technical support for the Community Preventive Services Task Force, an independent, nonfederal panel of public health and prevention experts. The panel provides evidence-based findings and recommendations about community preventive services, programs, and policies to improve health. Its members represent a broad range of research, practice, and policy expertise in community preventive services, public health, health promotion, and disease prevention.

CDC programs contribute subject matter experts to participate, and sometimes take the lead, in conducting systematic reviews for The Community Guide (http://www.thecommunityguide.org/index.html). The Community Guide is a resource that provides evidence-based recommendations and findings developed by the panel about what programs and policies work to improve public health and prevent disease in the community.306 The Community Guide includes recommendations on effective community-based skin cancer prevention interventions (see Table B on page 81 and http://www.thecommunityguide.org/cancer/index.html). Recommendations are periodically updated to reflect the latest scientific evidence.

CDC has also led communications campaigns designed to reduce UV exposure among individuals and in communities. HHS and CDC sponsored the Choose Your Cover Campaign, a 5-year skin cancer prevention and education campaign that ended in May 2003 (some campaign materials are available at http://www.cdc.gov/cancer/dcpc/publications/skin.htm).425 In 2014, CDC sponsored The Burning Truth communication initiative, which encourages individuals to keep their skin healthy and beautiful for life by protecting themselves from too much exposure to UV rays from the sun and tanning beds. For more information, see http://www.cdc.gov/cancer/skin/burningtruth.

In addition, CDC provides technical assistance to grantees that receive funding under the National Comprehensive Cancer Control Program (NCCCP). CDC suggests that funded programs address skin cancer prevention through the use of evidence-based interventions and promising environmental strategies to reduce UV exposure.

## Comprehensive Cancer Control Programs and Coalitions

CDC funds 65 programs in states, territories, Pacific Island jurisdictions, and tribes/tribal organizations through the NCCCP to establish broad-based comprehensive cancer control (CCC) coalitions, assess the burden of cancer, and develop and implement CCC plans to reduce cancer incidence and mortality.426 Each program uses cancer incidence data to identify high-priority cancers. Some CCC plans identify melanoma as a problem in their communities and have objectives that address prevention. A review of published cancer plans identified 25 CCC plans that addressed sun safety in their goals or objectives, and 18 had chapters or sections devoted to discussion of UV exposure, sun protection, or skin cancer prevention.427

During 2007–2012, nine CCC programs received additional funding to implement skin cancer programs in various settings. Common intervention settings and strategies include school-based education and policies, educational outreach in recreational settings (e.g., pools, beaches, camps, and golf courses), environmental approaches in child care settings to reduce UV exposure, and education about the risks of indoor tanning.304 Analysis of NCCCP programmatic data in 2013 revealed that 16 CCC coalitions have a skin cancer workgroup, and 13 CCC programs have annual objectives that specifically address preventing skin cancer in their action plans submitted to CDC.428 Many objectives use strategies designed to improve education or knowledge in various settings to educate children, adolescents, and adults about how to reduce UV exposure from the sun and from indoor tanning.

In addition, many CCC programs are working with partners to address skin cancer prevention through environmental approaches that reach more people in the community, such as increased shade in recreational settings and schools. Two CCC programs are working with their partners on long-term objectives to reduce indoor tanning among adolescent females. Three NCCCP awardees received funding and technical assistance to use policy and environmental approaches for cancer control to address skin cancer prevention. Activities included educating stakeholders about the link between artificial UV exposure and melanoma and developing shade structure policies.

## Agency for Healthcare Research and Quality

AHRQ provides scientific and administrative support for the independent U.S. Preventive Services Task Force (USPSTF). The USPSTF, in partnership with an AHRQ Evidence-Based Practice Center, completed a systematic evidence review on behavioral counseling in primary care to prevent skin cancer. The evidence review, the final USPSTF recommendations, and a consumer guide are available at http://www.uspreventiveservicestaskforce.org/uspstf/uspsskco.htm. Information about skin cancer screening is also available on the USPSTF website.

As part of its mission to improve health care, from primary prevention to chronic care management, AHRQ is exploring how to develop, strengthen, and sustain relationships among primary care practices, the community, and public health organizations in order to meet the needs of patients and families. These efforts are valuable to groups working to improve skin cancer prevention. To learn more, visit Building Relationships Between Clinical Practices and the Community to Improve Care on the AHRQ website (http://www.innovations.ahrq.gov/linkingClinicalPractices.aspx).

The AHRQ Innovations Exchange website (http://www.innovations.ahrq.gov) provides information about specific skin cancer prevention tools, such as how to use interactive kiosks, provide skin cancer screening and education at beaches, and work with members of the deaf community to improve cancer awareness (http://www.innovations.ahrq.gov/innovations_qualitytools.aspx?search=skin cancer).

## U.S. Food and Drug Administration

At the federal level, FDA regulates indoor UV tanning devices under separate authorities, both as medical devices and as radiation-emitting electronic products. FDA published a performance standard (21 CFR 1040.20) to set requirements for indoor tanning devices in 1979 and amended this standard in 1985 to accommodate devices that emitted primarily UVA radiation.348 FDA's current performance standard requires that a sunlamp product's label include a recommended exposure schedule (see example at http://tanresponsibly.com/uv-light).358 FDA has advised manufacturers that this schedule should provide for exposures of no more than three sessions in the first week.358 The performance standard contains requirements for the warning label on the product, the proportion of shortwave UV radiation, timer settings, and transmittance requirements for protective eyewear supplied with the device.

FDA inspectors inspect the manufacturing sites of sunlamp products (as resources allow) to verify compliance with FDA's performance standard. FDA also provides “model state regulations” for sunlamp products as guidance for states to use in their radiation protection programs. State inspectors routinely inspect tanning salons to ensure that the equipment in the salons carries appropriate labeling and a timer control as required by the FDA performance standard, in addition to any state requirements for operator training or procedures to ensure proper hygiene.

Under its medical device authority, FDA originally classified indoor tanning devices as low risk (Class I) medical devices.351,429 However, based on advice from its advisors and consultants at a March 2010 Advisory Committee meeting and review by agency experts, the agency issued a final order in May 2014 that reclassified sunlamp products as moderate to high risk (Class II) devices.349,350 Once effective, the order requires manufacturers of sunlamps to include a visible black box warning on the device that people younger than age 18 years should not use these devices. Manufacturers must receive 510(k) premarket clearance from FDA for newly marketed devices, which were previously exempt from any premarket review. Manufacturers must demonstrate that their products have met certain performance testing requirements, address certain product design characteristics, and provide comprehensive labeling that presents consumers with clear information on the risks of use.

FDA also regulates over-the-counter drugs, including sunscreens. Under labeling changes that became effective in 2012, sunscreens labeled as both broad spectrum and SPF 15 (or higher) are labeled as reducing the risk of skin cancer and reducing the risk of early skin aging caused by the sun if they are used as directed and in combination with other sun protection measures. All sunscreen products are labeled as helping to prevent sunburn. Any product that is not broad spectrum, or that is broad spectrum but has an SPF of at least 2 but less than 14, will have a warning stating that the product has been shown only to help prevent sunburn, not skin cancer or early skin aging. In 2011, FDA proposed limiting the maximum SPF on sunscreen labels to “50+”, because FDA did not have adequate data to show that products with an SPF higher than 50 provide any additional benefit compared with products with an SPF of 50 or lower (http://www.fda.gov/forconsumers/consumerupdates/ucm258416.htm).

## Federal Trade Commission

The Federal Trade Commission (FTC) is responsible for investigating false, misleading, and deceptive advertising claims about products and services, including tanning devices. In May 2010, the agency issued a complaint and final order against the Indoor Tanning Association (ITA).361 Among other things, the complaint alleged that ITA's advertising materials had represented that (1) tanning, including indoor tanning, does not increase the risk of skin cancer; (2) tanning, including indoor tanning, poses no danger; (3) indoor tanning is approved by the government; and (4) indoor tanning is safer than tanning outdoors because, in indoor tanning facilities, the amount of UV light is monitored and controlled. The complaint charged that these claims were false.

The settlement reached in this case bars ITA from making deceptive claims in the future and requires certain ITA advertisements to include health disclosures. In response to public comments opposing FTC's action, the agency noted that its investigation was informed by a thorough analysis of the available scientific evidence, including review of relevant scientific studies and consultation with experts from government, academia, and the industry. In connection with the ITA case, FTC released a consumer alert, stating that UV radiation from tanning devices damages the skin and poses serious health risks, including cancer, and that tanning is not necessary to get the health benefits of vitamin D.430

## U.S. Environmental Protection Agency

To help people plan outdoor activities so they can reduce UV exposure, the National Weather Service and EPA publish the UV Index, a forecast of the risk of overexposure to UV radiation from the sun at a given location, date, and time. For more information, visit the following websites: http://www.epa.gov/sunwise/uvindex.html, http://www.epa.gov/sunwise/uviresources.html, or http://www2.epa.gov/sunwise/uv-index-scale.431,432 The index ranges from 0 to 11+, with higher values indicating greater risk of overexposure. The forecast is calculated every day on the basis of the angle of the sun, ozone levels, expected cloud cover, and other local conditions.

In 2000, EPA launched SunWise, a health and environmental education program that teaches children and their caregivers how to protect themselves from overexposure to the sun. For more information about SunWise, visit the EPA website at http://www.epa.gov/sunwise.

## National Park Service

The National Park Service (NPS), a bureau within the U.S. Department of the Interior, offers recreational opportunities for about 275 million visitors every year and manages 401 parks throughout the United States. For nearly 100 years, NPS has contributed to the health and well-being of Americans by providing places that inspire physical activity, promote physical and mental health, and foster community through the preservation of ecosystems and interpretation of a shared heritage. Hand in hand with its efforts to provide opportunities for fun in the most beautiful outdoor environments in the country, NPS is also dedicated to educating the public about the importance of sun protection.

NPS has collaborated with partners such as the EPA SunWise program and the National Council on Skin Cancer Prevention to educate the public about ways to enjoy our nation's treasures while keeping safe in the sun. In 2012, NPS and its partners created a public service announcement on sun safety to be used for the annual “Don't Fry Day” campaign (http://www2.epa.gov/sunwise/dont-fry-day). In addition, NPS teamed up with other federal partners to create a “Healthy Parks, Healthy People” sun-safety window display to educate the public on how to safely engage in outdoor activities in our national parks while preventing overexposure to harmful sun rays. NPS's Safe Adventures program bases its prevention strategies on science to promote well-being and outdoor recreation while providing tools, information, and guidance that empower the public to have a safe adventure in national parks.

## Occupational Safety and Health Administration

The general duty clause of the Occupational Safety and Health Act states the following in Section 5(a)(1): “Each employer shall furnish to each of his employees employment and a place of employment which are free from recognized hazards that are causing or are likely to cause death or serious physical harm to his employees.”433 The Occupational Safety and Health Administration (OSHA) does not mandate employee exposure limits specific to UV radiation.434 OSHA's Campaign to Prevent Heat Illness in Workers is designed to raise awareness and educate workers and employers about the dangers of working in the heat. OSHA collaborates with the National Oceanic Atmospheric Administration and other federal agencies, such as EPA and CDC, for a joint public information notice for sun-safety awareness and participates in the National Council on Skin Cancer Prevention's “Don't Fry Day.”435,436

## Affordable Care Act

The Affordable Care Act (Section 10907) created a 10% excise tax on indoor tanning services, which became effective on July 1, 2010.^390^ The tax is only applicable to UV tanning services, excluding phototherapy sessions performed by a licensed medical professional. Tanning devices sold directly to consumers, facilities that offer tanning as an additional service to members without a separate fee, and sunless tanning products are not subject to the tax. The Affordable Care Act also requires that nongrandfathered health plans offered in the individual or group market provide benefits for and prohibit the imposition of cost-sharing requirements for USPSTF-recommended preventive services with a rating of “A” or “B.” This requirement includes the USPSTF recommendation to counsel children, adolescents, and young adults aged 10–24 years with fair skin about minimizing their exposure to UV radiation to reduce risk of skin cancer (B rating). For this type of recommendation, which only applies to a specific population, decisions about whether an individual is part of this population and should receive the given preventive service should be made by the attending provider.437,438