# Success Stories in Skin Cancer Prevention

## Federal Resources for Skin Cancer Prevention in Schools

A 2002 CDC report, Guidelines for School Programs to Prevent Skin Cancer,420 reviewed both the scientific evidence on skin cancer prevention and current school practices. It suggested guidelines for a comprehensive approach to skin cancer prevention in schools through policies, environmental change, education, family involvement, professional development, health services, and evaluation.

To support schools' implementation of these guidelines and to help schools create and maintain a physical environment that would support sun safety by ensuring that school grounds have adequate shade, CDC subsequently created a manual for schools called Shade Planning for America's Schools.308 The manual outlines steps that school communities can take to develop a comprehensive approach to reducing the risk of skin cancer, including strategies for providing shade at schools, an overview of how to plan a shade project, success stories from schools and school districts that have completed shade planning projects, and information on how to conduct a shade audit. CDC also created the Sun Safety for America's Youth Toolkit, a resource for local comprehensive cancer control programs.421 It outlines a step-by-step process for program planning, suggests strategies for implementing sun protection education in schools, and provides sample evaluation questions.421

## RAYS Skin Cancer Prevention Program Shines Bright for New Mexico Schoolchildren

The RAYS (Raising Awareness in Youth About Sun Safety) Project provides funding and technical support to elementary schools and community organizations across New Mexico to implement sun-safety education. It is supported by the New Mexico Department of Health Comprehensive Cancer Program. The RAYS Project uses various evidence-based and preapproved curricula, including Sunny Days, Healthy Ways, the SunSmart Project, and the U.S. Environmental Protection Agency's (EPA's) SunWise Program.

Many RAYS Project schools have changed policies on their campuses to support sun protection, including changing recess times to avoid peak UV exposure, allowing students to wear hats and sunglasses, and providing shade on playgrounds. English- and Spanish-language materials have been developed for parents and have been distributed to various audiences statewide. RAYS Project contractors also include sun-safety education from evidence-based programs in other health-related school and community events.422

For more information about the RAYS Project and other CDC-supported Comprehensive Cancer Control Programs working on skin cancer prevention, visit http://www.cdc.gov/cancer/ncccp/pdf/success/SuccessStories.pdf.

## City of Toronto Shade Policy

The City of Toronto in Ontario, Canada, enacted a citywide shade policy in 2007. The shade policy states that providing shade can be an effective way to reduce exposure to UV radiation and its associated health risks, such as skin cancer. Furthermore, the presence of shade can encourage physical activity, reduce greenhouse gas and air pollutant emissions, lessen the urban heat island effect, and reduce energy costs. Under the policy, providing shade, either natural or constructed, should be an essential element when planning for and developing new city facilities, such as parks or public spaces, and in refurbishing existing city-owned and city-operated facilities and sites. Increasing shade in Toronto contributes to a healthier and more sustainable city.

In 2010, the City of Toronto developed shade guidelines to help implement the shade policy. For more information, visit http://www1.toronto.ca/health/shadeguidelines. The shade policy and guidelines were created by the Ultraviolet Radiation and Shade Working Group of the Toronto Cancer Prevention Coalition with the support of Toronto Public Health, the Toronto Board of Health, and the Toronto City Council.