# Skin Cancer Screening

Some groups recommend periodic skin cancer screening,^a^ either by a health care provider or by self-examination.290,291 Consistent and regular screening identifies melanomas that are, on average, thinner than those found during usual care. Whether detection of these lesions leads to fewer cases of disease or death is unknown.292 For this reason, the independent U.S. Preventive Services Task Force (USPSTF) has stated that current evidence is insufficient^b^ to recommend skin cancer screening by primary care providers among the general U.S. adult population. On May 15, 2014, the USPSTF released a draft research plan that will be used to guide a systematic review of the evidence by researchers.293 Despite the insufficient evidence supporting screening in the general population, an estimated 87% of Americans believe that skin cancer screening is recommended.244

a Skin cancer screening is defined as an evaluation of the skin by a medical provider, in the absence of changes to the skin.

b The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of this service. Evidence is lacking, of poor quality, or conflicting, and the balance of benefits and harms cannot be determined.

Although screening is not currently recommended, providers should remain alert to suspicious lesions. The USPSTF states the following: “Clinicians should remain alert for skin lesions with malignant features noted in the context of physical examinations performed for other purposes. Asymmetry, border irregularity, color variability, diameter greater than 6 mm (ABCD criteria), or rapidly changing lesions are features associated with an increased risk for cancer. Biopsy of suspicious lesions is warranted.”

A recent study conducted in one state in Germany found that population-based screening was associated with reduced melanoma death rates.418 Although the results are promising, some of these reductions occurred before implementation of the screening portion of the study, which suggests that some of the reduction could be due to increased awareness among the population as a result of the communications campaign related to the screening program. Screening did not reduce melanoma deaths in a recent study in Switzerland, a country with a particularly high incidence of cutaneous melanoma, implying that other primary and secondary strategies may be more effective.419

Further studies are needed to determine the effectiveness of screening among the general population. Research is also needed to determine the relative benefits and cost benefits of various screening strategies, particularly in a diverse population like that of the United States, where wide variations exist in environmental UV exposure and the geographic latitude (and thus the UV intensity) of where people live.