# Scope and Definitions

This document focuses on the three most common types of skin cancers: basal cell carcinoma (BCC), squamous cell carcinoma (SCC), and melanoma, which together account for more than 99% of skin cancers.41,42 This document also focuses only on cutaneous skin cancers and not other types, such as SCCs that occur on the genitals (and which generally have different risk factors, notably human papillomavirus) or noncutaneous types of melanoma, such as ocular.

## Types of Skin Cancer

Skin cancer arises from the uncontrolled growth of different types of cells found normally in skin. The most common types are BCC and SCC. Although these cancers are rarely deadly, they are very common and potentially disfiguring, and they often recur. People diagnosed with SCCs and BCCs, especially at younger ages, are at increased risk of subsequent primary cancers, possibly for genetic reasons.412,413

### Basal Cell Carcinomas

BCCs arise from the cells in the bottom, or basal, layer of the epidermis. BCCs tend to occur on skin that is chronically exposed to the sun, such as the face, head, and neck, but they also frequently occur on the trunk of the body.43 Because it frequently occurs on the face and head, BCC and its treatment can result in noticeable disfigurement. This disease can be classified into five subtypes: nodular, ulcerating, pigmented, sclerosing, and superficial.414

### Squamous Cell Carcinomas

SCCs arise from squamous cells in the outer layers of the epidermis. Similar to BCCs, SCCs usually occur in prominent, sun-exposed areas, like the face, head, and neck.43 SCCs often arise from actinic keratoses, which are rough, scaly patches that occur on sun-exposed areas.414

### Melanomas

Melanomas develop from melanocytes, the melanin-producing cells that give skin and eyes their color.32 These cancers can arise in the skin (cutaneous melanoma) and less frequently in the eye (ocular melanoma) or mucous membranes. Melanoma can be classified into several subtypes: nodular and superficial spreading melanomas, which can occur in any location on the body; lentigo maligna melanoma, which is usually found on the head, neck, and face; and acral lentiginous melanoma, which arises on the palms of the hands and soles of the feet, and under nails.32,57

## Types of Ultraviolet Exposure

### Overexposure

Overexposure or excessive exposure, as used in this document, means any ultraviolet (UV) exposure that is likely to increase a person's risk of skin cancer, without conferring benefits beyond those that can be achieved through more limited outdoor exposures. Overexposure frequently results in tanned or sunburned skin. Seeking a tan (whether indoor tanning or outdoor sunbathing) is considered overexposure for the purpose of this document. Sunbathing and indoor tanning are common methods of skin tanning.

Unnecessary or avoidable exposures, as used in this document, are those UV exposures that can be easily avoided. Seeking a tan for cosmetic purposes, whether indoors or outdoors, is considered an unnecessary exposure. Some outdoor exposures are necessary as part of daily routines, such as walking for transportation, being outdoors for physical activity, or working outdoors. Sun protection can be used to reduce risks of unavoidable exposure.

Erythema, or sunburn, is defined as an acute cutaneous inflammatory reaction to UV exposure, with classic signs of inflammation, such as redness, warmth, tenderness, and edema.415 Sunburn is a clear indication of overexposure. However, a person can have suffered overexposure even in the absence of signs of sunburn.128,183,184

### Limited Exposure

Limited exposure to UV radiation, as used in this document, refers to very brief (5–15 minute) outdoor exposures received during the course of daily activities or exposures at very low UV Index levels (2 or less). For most people, the risk of skin cancer from such limited, incidental UV exposure is likely low. However, damage from UV radiation is cumulative, so even limited exposures can result in harm over time.

The risks and benefits of UV exposure vary by individual, as well as by environmental conditions, such as weather, altitude, latitude, and the presence of reflective surfaces, such as snow, sand, or water. For a very fair-skinned person in the summer sun at low latitudes or high altitudes, even a very short time outdoors could lead to overexposure, especially in highly reflective environments, such as areas that are snowy, sandy, or near bodies of water.135-137,181

Conversely, for a very dark-skinned person, short exposures may not be enough to achieve sufficient vitamin D levels, especially in the winter in northern climates.178 Skin pigmentation can also vary within individuals. For example, some people have vitiligo, a condition in which the melanocytes in some areas of the skin do not function, resulting in patches of depigmented skin that are sensitive to UV radiation.416 Current evidence indicates that UV exposures below the amount needed to induce sunburn, including exposures that result in a tan, can also increase skin cancer risk.128,183,184,292,417