# Acknowledgements

The Surgeon General's Call to Action to Prevent Skin Cancer was prepared by the Centers for Disease Control and Prevention under the direction of the Office of the Surgeon General. These agencies are part of the U.S. Department of Health and Human Services, which published the Call to Action.

- Rear Admiral (RADM) Boris D. Lushniak, M.D., M.P.H.
  Acting Surgeon General
- Howard K. Koh, M.D., M.P.H.
  Assistant Secretary for Health
- Thomas R. Frieden, M.D., M.P.H.
  Director, Centers for Disease Control and Prevention

LEAD WRITERS
- Meg Watson, M.P.H.
  Centers for Disease Control and Prevention
- Erin Garnett, M.P.H.
  McNeal Professional Services
- Gery P. Guy, Jr., Ph.D., M.P.H.
  Centers for Disease Control and Prevention
- Dawn M. Holman, M.P.H.
  Centers for Disease Control and Prevention

CONTRIBUTORS
- Zahava Berkowitz, M.S.P.H.
  Centers for Disease Control and Prevention
- Mary Beth Bigley, Dr.P.H., M.S.N., A.N.P. a
  a Dr. Bigley is now at the Health Resources and Services Administration.
  Office of the Surgeon General
- Benjamin Bishop, Pharm.D., M.P.H.
  U.S. Food and Drug Administration
- L. Casey Chosewood, M.D.
  National Institute for Occupational Safety and Health
- CAPT Robert DeMartino, M.D.
  Office of the Surgeon General
- Donatus Ekwueme, Ph.D.
  Centers for Disease Control and Prevention
- David Espey, M.D.
  Centers for Disease Control and Prevention
- Janet Evans, J.D.
  Federal Trade Commission
- Jeff Glenn, M.P.A.
  Centers for Disease Control and Prevention
- Anne Hartman, M.S.
  National Cancer Institute, National Institutes of Health
- Rosie Henson, M.S.S.W., M.P.H.
  Office of the Assistant Secretary for Health, U.S.
  Department of Health and Human Services
- Sherry Everett Jones, Ph.D., M.P.H., J.D.
  Centers for Disease Control and Prevention
- Robert Landolfi, Jr., M.S.
  U.S. Environmental Protection Agency
- Markham Luke, M.D., Ph.D.
  U.S. Food and Drug Administration
- Greta M. Massetti, Ph.D.
  Centers for Disease Control and Prevention
- David Meyers, M.D.
  Agency for Healthcare Research and Quality
- Sharon Miller, M.S.E.E.
  U.S. Food and Drug Administration
- CDR Sara Newman, Dr.P.H., M.C.P.
  National Park Service
- Melissa Palmer, M.P.H.
  Centers for Disease Control and Prevention
- Douglas Perin, M.P.H.
  Centers for Disease Control and Prevention
- Frank Perna, Ed.D., Ph.D.
  National Cancer Institute, National Institutes of Health
- Marcus Plescia, M.D., M.P.H. b
  b Dr. Plescia is now at the Mecklenberg County Health Department in North Carolina.
  Centers for Disease Control and Prevention
- Samuel F. Posner, Ph.D.
  Centers for Disease Control and Prevention
- Linda Rutsch, M.P.H., M.B.A.
  U.S. Environmental Protection Agency
- Jinan Saadine, M.D.
  Centers for Disease Control and Prevention
- Param Sandhu, M.P.H.
  Centers for Disease Control and Prevention
- Mona Saraiya, M.D., M.P.H.
  Centers for Disease Control and Prevention
- Kelley S. Scanlon, Ph.D.
  Centers for Disease Control and Prevention
- Peter Schmeissner, Ph.D.
  Office of the Surgeon General
- Meredith Shoemaker, M.P.H.
  Centers for Disease Control and Prevention
- Martina Taylor, M.T.
  National Cancer Institute, National Institutes of Health
- Cheryll C. Thomas, M.P.H.
  Centers for Disease Control and Prevention
- Julie Townsend, M.S.
  Centers for Disease Control and Prevention
- Lydia Velazquez, Pharm.D.
  U.S. Food and Drug Administration
- Mary C. White, Sc.D.
  Centers for Disease Control and Prevention

REVIEWERS
- Dawn Alley, Ph.D.
  Office of the Surgeon General
- Peter Briss, M.D., M.P.H.
  Centers for Disease Control and Prevention
- David B. Buller, Ph.D.
  Klein Buendel, Inc.
- Jannie G. Ferrell
  National Oceanic and Atmospheric Administration
- Paul Gadiock, J.D.
  U.S. Food and Drug Administration
- DeAnn Lazovich, Ph.D.
  University of Minnesota
- Larry McGowan, M.E., C.I.H., C.S.P.
  Occupational Safety and Health Administration
- Martin A Weinstock, M.D., Ph.D.
  U.S. Department of Veterans Affairs

DATA ASSISTANCE
- Jessica King, M.P.H
  Centers for Disease Control and Prevention
- Trevor Thompson
  Centers for Disease Control and Prevention
- Hannah Weir, Ph.D.
  Centers for Disease Control and Prevention

EDITING AND LAYOUT
- Amanda Crowell
  Centers for Disease Control and Prevention
- Renee Maciejewski
  Centers for Disease Control and Prevention

COMMUNICATIONS
- Janine Cory, M.P.H.
  Centers for Disease Control and Prevention
- Kate Migliaccio, M.P.H.
  Office of the Assistant Secretary for Health
- Domenica Niño, M.P.H.
  Centers for Disease Control and Prevention
- Karen Silver, M.P.H.
  Office of the Surgeon General